# Appendix D—Obtaining Screening and Assessment Tools

Addiction Severity Index National Technical Information Service Order Desk 5285 Port Royal Road Springfield, VA 22161 Phone: (888) 584-8332 Fax: (703) 605-6900 Email: info@ntis.fedworld.gov Web site: http://www.ntis.gov

Beck Depression Inventory The Psychological Corporation 555 Academic Court San Antonio, TX 78204-3956 Phone: (800) 622-3231 Email: Customer_Service@hbtpc.com Web site: http://www.hbtpc.com

Brief Symptom Inventory NCS Assessment P.O. Box 1416 Minneapolis, MN 55440 Phone: (800) 627-7271 Email: assessments@ncs.com Web site: http://www.ncs.com

Childhood Maltreatment Interview Schedule John Briere, Ph.D. Department of Psychiatry and Behavioral Sciences University of Southern California School of Medicine 1937 Hospital Place Los Angeles, CA 90033 Phone: (213) 226-5697 Email: jbriere@hsc.usc.edu

Childhood Trauma Interview Laura Fink, Ph.D. c/o Josephine Dodge Bronx VA Medical Center Psychiatry Service 116A 130 West Kingsbridge Road Bronx, NY 10468 Phone: (718) 584-9000 x 6990 Email: dodge.j@bronx.va.gov

Childhood Trauma Questionnaire NCS Assessment P.O. Box 1416 Minneapolis, MN 55440 Phone: (800) 627-7271 Email: assessments@ncs.com Web site: http://www.ncs.com

Clinician-Administered PTSD Scale Frank W. Weathers, Ph.D. National Center for PTSD Boston VA Medical Center (116B) 150 South Huntington Avenue Boston, MA 02130 Phone: (617) 232-9500 Email: ptsd@dartmouth.edu Web site: http//www.dartmouth.edu/dms/ptsd

Diagnostic Interview Schedule Lee Robins, Ph.D. Department of Psychiatry, Box 8134 Washington University School of Medicine 4940 Children's Place St. Louis, MO 63110 Phone: (314) 362-2469 Email: robins@epi.wustl.edu

Dissociative Experiences Scale The Sidran Foundation 2328 West Joppa Road, Suite 15 Lutherville, MD 21093 Phone: (410) 825-8888 Email: sidran@sidran.org Web site: http://www.sidran.org

Evaluation of Lifetime Stressors (Test #2) Karen Krinsley, Ph.D. National Center for PTSD (116B-2) Boston VA Medical Center 150 South Huntington Avenue Boston, MA 02130 Phone: (617) 232-9500 Email: ptsd@dartmouth.edu Web site: http//www.dartmouth.edu/dms/ptsd

MINI International Neuropsychiatric Interview Medical Outcome Systems 10440 Rolling Brook Court Jacksonville, FL 32256 Phone: (904) 363-6246 Email: questions@medical-outcomes.com Web site: http://www.medical-outcomes.com

Modified PTSD Symptom Scale: Self-Report Version Sherry Falsetti, Ph.D. National Crime Victims Research and Treatment Center Department of Psychiatry and Behavioral Sciences Medical University of South Carolina 171 Ashley Avenue Charleston, SC 29425-0742 Phone: (803) 792-2945 Email: falseta@musc.edu Web site: http://www.musc.edu/cvc

National Women's Study Event History Dean Kilpatrick, Ph.D. National Crime Victims Research and Treatment Center Department of Psychiatry and Behavioral Sciences Medical University of South Carolina 171 Ashley Avenue Charleston, SC 29425-0742 Phone: (803) 792-2945 Email: kilptg@musc.edu Web site: http://www.musc.edu/cvc

Parent-Child Relationship Inventory (PCRI) University of Nebraska Press P.O. Box 880484 312 N. 14th Street Lincoln, NE 68588-0484 Phone: (800) 755-1105 FAX: (800) 526-2617 Web site: http://www.unl.edu/buros/13tests.html

Parental Acceptance and Rejection Questionnaire (PARQ) Handbook for the Study of Parental Acceptance and Rejection Center for the Study of Parental Acceptance and Rejection University of Connecticut Storrs, CT 06269 (860) 486-0073 Email: rohner@uconnvm.uconn.edu Web site: http://vm.uconn.edu/~rohner/

Penn Inventory for Posttraumatic Stress Disorder Melvyn Hammarberg, Ph.D. Department of Anthropology University of Pennsylvania 325 University Museum Philadelphia, PA 19104-6398 Phone: (215) 898-0981 Email: mhammarb@ccat.sas.upenn.edu Web site: http://www.sas.upenn.edu/anthro/faculty/profiles/hammarberg.html

Posttraumatic Stress Diagnostic Scale NCS Assessment P.O. Box 1416 Minneapolis, MN 55440 Phone: (800) 627-7271 Email: assessments@ncs.com Web site: http://www.ncs.com

Profile of Mood States Educational and Industrial Testing Service P.O. Box 7234 San Diego, CA 92167 Phone: (800) 416-1666 Email: edits@worldnet.att.net Web site: http://www.edits.net

Psychiatric Research Interview for Substance and Mental Health Disorders Deborah Hasin, Ph.D. Research Assessment and Training New York State Psychiatric Institute 722 West 168th Street New York, NY 10032 Phone: (212) 543-5000 Email: hasind@nypdrat.cpmc.columbia.edu Web site: http://nyspi.cpmc.columbia.edu

Schedule for Affective Disorders and Schizophrenia Jean Endicott, Ph.D. Research Assessment and Training New York State Psychiatric Institute 722 West 168th Street New York, NY 10032 Phone: (212) 543-5000 Email: je10@columbia.edu Web site: http://nyspi.cpmc.columbia.edu

Screen for Posttraumatic Stress Symptoms Eve Carlson, Ph.D. Clinical Psychology Associates 611 East Walworth Avenue Delavan, WI 53115 Phone: (414) 740-9191

Structured Clinical Interview for DSM-IV Axis I Disorders American Psychiatric Press, Inc. 1400 K Street, N.W. Washington, DC 20005 Phone: (800) 369-5777 Email: csdept@appi.org Web site: http://www.appi.org

Symptom Checklist-90-Revised NCS Assessment P.O. Box 1416 Minneapolis, MN 55440 Phone: (800) 627-7271 Email: assessments@ncs.com Web site http://www.ncs.com

Trauma Assessment for Adults (TAA)-Self-Report Heidi Resnick, Ph.D. National Crime Victims Research and Treatment Center Department of Psychiatry and Behavioral Sciences Medical University of South Carolina 171 Ashley Avenue Charleston, SC 29425-0742 Phone: (803) 792-2945 Email: resnickh@musc.edu Web site: http://www.musc.edu/cvc

Trauma Symptom Checklist-40 John Briere, Ph.D. Department of Psychiatry and Behavioral Sciences University of Southern California School of Medicine 1937 Hospital Place Los Angeles, CA 90033 Phone: (213) 226-5697 Email: jbriere@hsc.usc.edu

Trauma Symptom Inventory Psychological Assessment Resources, Inc. P.O. Box 998 Odessa, FL 33556 Phone: (800) 331-8378 Email: custserv@parinc.com Web site: http://www.parinc.com