# Appendix A --Bibliography

Allen, D.; Lovejoy-Johnson, A.; Holloway, E.; Robbins, J.; and Woods, S. Fostering collaboration: Substance abuse providers working together. Common Ground. 1996;January.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (DSM-IV), 4th ed. Washington, DC: American Psychiatric Association. 1994.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance-Related Disorders, 2nd ed. Chevy Chase, MD: American Society of Addiction Medicine. 1996.
Anthony, J.C.; Warner, L.A.; and Kessler, R.C. Comparative epidemiology of dependence on tobacco, alcohol, controlled substances, and inhalants: Basic findings from the National Comorbidity Survey. Experimental and Clinical Psychopharmacology. 1994;2:244-268.
Armstrong, J. Psychological assessment. In: Spira, J.L., and Yalom, I.D., eds. Treating Dissociative Identity Disorder. San Francisco: Jossey-Bass. 1996.
Arroyo, J.A.; Simpson, T.L.; and Aragon, A.S. Childhood sexual abuse among Hispanic and non-Hispanic White college women. Hispanic Journal of Behavioral Sciences. 1997;19(1):57-68.
Barker, L.R., and Whitfield, C.L. Alcoholism. In: Barker, L.R.; Burton, J.R.; and Zeive, P.D., eds. Principles of Ambulatory Medicine. Baltimore: Williams & Wilkins. 1991.
Barnett, D.; Manly, J.T.; and Cicchetti, D. Continuing toward an operational definition of psychological maltreatment. Development and Psychopathology. 1991;3:19-29.
Baumrind, D. Current patterns of parental authority. Developmental Psychology Monographs 4:1, Pt. 2. 1971.
Beck, A.T. 1967.
Beck, A.T., and Beck, R.W. Screening depressed patients in family practice: A rapid technic. Postgraduate Medicine. 1972;52(6):81-85. [pmid: 4635613].
Beckman, L.J., and Ackerman, K.T. Women, alcohol, and sexuality. In: Galanter, M., ed. Recent Developments in Alcoholism. Vol. 12, Women and Alcoholism. New York: Plenum Press. 1995.
Beitchman, J.H.; Zucker, K.J.; Hood, J.E.; daCosta, G.A.; Akman, D.; and Cassavia, E. A review of the long-term effects of child sexual abuse. Child Abuse and Neglect. 1992;16:101-118.
Belsky, J. The determinants of parenting: A process model. Child Development. 1984;55:83-96.
Belsky, J. Etiology of child maltreatment: A developmental-ecological analysis. Psychological Bulletin. 1993;114(3):413-434. [pmid: 8272464].
Bennett, E.M., and Kemper, K.J. Is abuse during childhood a risk factor for developing substance abuse problems as an adult?. Journal of Developmental and Behavioral Pediatrics. 1994;15:426-429.
Benward, J., and Densen-Gerber, J. Incest as a causative factor in anti-social behavior: An exploratory study. Contemporary Drug Problems. 1975;4:323-340.
Berkowitz, M. Therapist survival: Maximizing generativity and minimizing burnout. Psychotherapy in Private Practice. 1987;5:85-89.
Bernstein, D.P.; Fink, L.; Handelsman, L.; Foote, J.; Lovejoy, M.; Wenzel, K.; Sapareto, E.; and Ruggiero, J. Initial reliability and validity of a new retrospective measure of child abuse and neglect. American Journal of Psychiatry. 1994;151(8):1132-1136. [pmid: 8037246].
Bernstein, E.M., and Putnam, F.W. Development, reliability, and validity of a dissociation scale. Journal of Nervous and Mental Disease. 1986;174(12):727-735. [pmid: 3783140].
Besharov, D.J. 1990.
Besharov, D.J., and Laumann, L.A. Don't call it child abuse if it's really poverty. Journal of Children and Poverty. 1997;3(1):5-36.
Bisbey, L.B. "No Longer a Victim: A Treatment Outcome Study of Crime Victims With Post-Traumatic Stress Disorder." Ph.D. dissertation, California School of Professional Psychology, San Diego, 1995. University Micro Films International Pub. No.: 952269. 1994.
Blake, D.D. Rationale and development of the clinician-administered PTSD scales. PTSD Research Quarterly. 1994;5:1-2.
Blake, D.D.; Weathers, F.W.; Nagy, L.M.; Kaloupek, D.G.; Gusman, F.D.; Charney, D.S.; and Keane, T.M. The development of a clinician-administered PTSD scale. Journal of Traumatic Stress. 1995;8(17):75-90. [pmid: 7712061].
Boundy, D. Profile: Project SAFE. 1998.
Bowman, E.S. Delayed memories of child abuse: Part II: An overview of research findings relevant to understanding their reliability and suggestibility. Dissociation: Progress in the Dissociative Disorders. 1996;9:232-243.
Boyd, C.; Henderson, D.; Ross-Durow, P.; and Aspen, J. Sexual trauma and depression in African-American women who smoke crack cocaine. Substance Abuse. 1997;18:133-141.
Brabant, S.; Forsyth, C.J.; and LeBlanc, J.B. Childhood sexual trauma and substance misuse: A pilot study. Substance Use and Misuse. 1997;32(10):1417-1431. [pmid: 9286009].
Brady, K.T.; Killeen, T.; Saladin, M.E.; Dansky, B.; and Becker, S. Comorbid substance abuse and posttraumatic stress disorder. American Journal on Addictions. 1994;3:160-164.
Braun, B. The BASK model of dissociation. Dissociation. 1988;1:4-23.
Braver, M.; Bumberry, J.; Green, K.; and Rawson, R. Childhood abuse and current psychological functioning in a university counseling center population. Journal of Consulting and Clinical Psychology. 1992;39:252-257.
Bremner, J.D.; Randall, P.; Scott, T.M.; Bronen, R.A.; Seibyl, J.P.; Southwick, S.M.; Delaney, R.C.; McCarthy, G.; Charney, D.S.; and Innis, R.B. MRI-based measurement of hippocampal volume in patients with combat-related posttraumatic stress disorder. American Journal of Psychiatry. 1995;152(7):973-981. [pmid: 7793467].
Briere, J. Controlling for family variables in abuse effects research: A critique of the "partialling" approach. Journal of Interpersonal Violence. 1988;3:80-89.
Briere, J. 1989.
Briere, J. 1992.
Briere, J. Methodological issues in the study of sexual abuse effects. . Journal of Consulting and Clinical Psychology. 1992;60(2):196-203. [pmid: 1592948].
Briere, J. Trauma Symptom Inventory (TSI): Professional Manual. Odessa, FL: Psychological Assessment Resources. 1995.
Briere, J. Psychometric review of trauma symptom inventory (TSI). In: Stamm, B.H., ed. Measurement of Stress, Trauma, and Adaptation. Lutherville, MD: Sidran Press. 1996.
Briere, J. Psychological assessment of child abuse effects in adults. In: Wilson, J.P., and Keane, T.M., eds. Assessing Psychological Trauma and PTSD. New York: Guilford Press. 1997.
Briere, J., and Conte, J. Self-reported amnesia for abuse in adults molested as children. Journal of Traumatic Stress. 1993;6:21-31.
Briere, J.N., and Elliott, D.M. Sexual abuse, family environment, and psychological symptoms: On the validity of statistical control. Journal of Consulting and Clinical Psychology. 1993;61:284-288.
Briere, J.N., and Elliott, D.M. Immediate and long-term impacts of child sexual abuse. Future of Children. 1994;4(2):54-69. [pmid: 7804770].
Briere, J.; Evans, D.; Runtz, M.; and Wall, T. Symptomatology in men who were molested as children: A comparison study. American Journal of Orthopsychiatry. 1988;58:457-461.
Briere, J., and Runtz, M. The trauma symptom checklist (TSC-33): Early data on a new scale. Journal of Interpersonal Violence. 1989;4:151-163.
Briere, J., and Runtz, M. Augmenting Hopkins SCL scales to measure dissociative symptoms: Data from two nonclinical samples. Journal of Personality Assessment. 1990;55:376-379.
Briere, J., and Runtz, M. Differential adult symptomatology associated with three types of child abuse histories. Child Abuse and Neglect. 1990;14(3):357-364. [pmid: 2207804].
Briere, J., and Woo, R. 1991.
Briere, J., and Zaidi, L.Y. Sexual abuse histories and sequelae in female psychiatric emergency room patients. American Journal of Psychiatry. 1989;146(12):1602-1606. [pmid: 2589554].
Brown, B.S. Drug use-chronic and relapsing or a treatable condition?. Substance Use and Misuse. 1998;33:2515-2520.
Brown, D.; Scheflin, A.; and Whitfield, C.L. Recovered memories: The current weight of the evidence in science and in the courts. Journal of Psychiatry and Law. 1999;27(1):5-156.
Brown, H.M. Shame and relapse issues with the chemically dependent client. Alcoholism Treatment Quarterly. 1991;8(3):77-82.
Brown, P.J.; Recupero, P.R.; and Stout, R. PTSD substance abuse comorbidity and treatment utilization. Addictive Behaviors. 1995;20(2):251-254. [pmid: 7484319].
Brown, P.J.; Rubin, A.; Longabaugh, R.; Stout, R.; and Wolfe, J. 1993.
Browne, A., and Finkelhor, D. The impact of child sexual abuse: A review of the literature. Psychological Bulletin. 1986;99(1):66-77. [pmid: 3704036].
Bryer, J.B.; Nelson, B.A.; Miller, J.B.; and Krol, P.A. Childhood sexual and physical abuse as factors in adult psychiatric illness. American Journal of Psychiatry. 1987;144:1426-1430.
Buriel, R.; Loya, P.; Gonda, T; and Klessen, K. Child abuse and neglect referral patterns of Anglo and Mexican Americans. Hispanic Journal of Behavioral Sciences. 1979;1:215-227.
Burnam, M.A.; Stein, J.A.; Golding, J.M.; Siegel, J.M.; Sorenson, S.B.; Forsythe, A.B.; and Telles, C.A. Sexual assault and mental disorders in a community population. . Journal of Consulting and Clinical Psychology. 1988;56:843-850.
Burnett, B.B. The psychological abuse of latency age children: A survey. . Child Abuse and Neglect. 1993;17:441-454.
Cahill, C.; Llewelyn, S.P.; and Pearson, C. Long-term effects of sexual abuse which occurred in childhood: A review. British Journal of Clinical Psychology. 1991;30:117-130.
Carlson, E.B. 1997.
Carlson, E.B.; Putnam, F.W.; Ross, C.A.; Torem, M.; Coons, P.; Dill, D.L.; Loewenstein, R.J.; and Braun, B.G. Validity of the Dissociative Experiences Scale in screening for multiple personality disorders: A multicenter study. American Journal of Psychiatry. 1993;150(7):1030-1036. [pmid: 8317572].
Carran, D.T.; Nemerofsky, A.; and Kerins, M. Risk of unsuccessful program completion for students with serious emotional/behavioral disorders: An epidemiological risk analysis. Behavioral Disorders. 1996;21:172-189.
Carroll, K.M. Relapse prevention as a psychosocial treatment: A review of controlled clinical trials. In: Marlatt, G.A., and VandenBos, G.R., eds. Addictive Behaviors: Readings on Etiology, Prevention, and Treatment. Washington, DC: American Psychological Association. 1997.
Carter, J.H. Racism's impact on mental health. Journal of the National Medical Association. 1994;86:543-547.
Catalano, R.F.; Haggerty, K.P.; and Gainey, R.R. Prevention Approaches in Methadone Treatment Settings: Children of Drug Abuse Treatment Clients (SDRG Pub. No. 127). Seattle, WA: Social Development Research Group, University of Washington. 1993.
Catherall, D.R., and Shelton, R.B. Men's groups for posttraumatic stress disorder and the role of shame. In: Andronico, M.P., ed. Men in Groups: Insight, Interventions, and Psychoeducational Work. Washington, DC: American Psychological Association. 1996.
Cavalcade Productions. Vicarious Traumatization: (I) The Cost of Empathy; (II) Transforming the Pain. Two-tape set of training videos. Nevada City, CA: Cavalcade Productions. 1997.
Center for Substance Abuse Treatment. Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 7. DHHS Pub. No. (SMA) 94-2076. Washington, DC: U.S. Government Printing Office. 1994.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 14. DHHS Pub. No. (SMA) 95-3031. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, Number 23. DHHS Pub. No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office. 1996.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Physicians. Treatment Improvement Protocol (TIP) Series, Number 24. DHHS Pub. No. (SMA) 97-3139. Washington, DC: U.S. Government Printing Office. 1997.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Domestic Violence. Treatment Improvement Protocol (TIP) Series, Number 25. DHHS Pub. No. (SMA) 97-3163. Washington, DC: U.S. Government Printing Office. 1997.
Center for Substance Abuse Treatment. 1997.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 27. DHHS Pub. No. (SMA) 98-3222. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment. Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series, Number 30. DHHS Pub. No. (SMA) 98-3222. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment. Screening and Assessing Adolescents for Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 31. DHHS Pub. No. (SMA) 99-3282. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 32. DHHS Pub. No. (SMA) 99-3283. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 35. DHHS Pub. No. (SMA) 99-3354. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Integrating Substance Abuse Treatment and Vocational Services. Treatment Improvement Protocol (TIP) Series. Washington DC: U.S. Government Printing Office, in press (a).
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With HIV/AIDS. Treatment Improvement Protocol (TIP) Series. Washington, DC: U.S. Government Printing Office, in press (b).
Chasnoff, I.J.; Landress, H.J.; and Barrett, M.E. The prevalence of illicit-drug or alcohol use during pregnancy and discrepancies in mandatory reporting in Pinellas County, Florida. New England Journal of Medicine. 1990;322:1202-1206.
Chassin, L.; Curran, P.J.; Hussong, A.M.; and Colder, C.R. Relation of parent alcoholism to adolescent substance use: A longitudinal follow-up study. Journal of Abnormal Psychology. 1996;105:70-80.
Child Welfare League of America (CWLA). 1989.
Child Welfare League of America (CWLA). 1992.
Cicchetti, D., and Lynch, M. Toward an ecological/transactional model of community violence and child maltreatment. Psychiatry. 1993;5:696-718.
Cicchetti, D., and Lynch, M. Failures in the expectable environment and their impact on individual development: The case of child maltreatment. In: Cicchetti, D., and Cohen, D.J., eds. Developmental Psychopathology. Vol. 2, Risk, Disorder, and Adaptation. New York: John Wiley and Sons. 1995.
Clark, D.B.; Lesnick, L.; and Hegedus, A.M. Traumas and other adverse life events in adolescents with alcohol abuse and dependence. Journal of the American Academy of Child and Adolescent Psychiatry. 1997;36(12):1744-1751. [pmid: 9401336].
Clay, R.A. Public backlash buoys antimanaged-care laws. APA Monitor. 1999;29(3), 1998. http://www.apa.org/monitor/mar98/backlash.html [Accessed Jan. 27.
Coletti, S.; Hamilton, N.; and Donaldson, P. Operation PAR, Inc. PAR Village: Long-term treatment for women and their children: Process evaluation and research findings. In: Goldberg, S.; Barth, R.; and Vogel-Edwards, M., eds. Service Outcomes for Drug- and HIV-Affected Families. Berkeley, CA: National Abandoned Infants Assistance Resource Center. 1997.
Corey, M.S., and Corey, G. Groups: Process and Practice, 5th ed. Pacific Grove, CA: Brooks/Cole Publishing. 1996.
Cornell, W.F., and Olio, K.A. Integrating affect in treatment with adult survivors of physical and sexual abuse. American Journal of Orthopsychiatry. 1991;61(1):59-69. [pmid: 2006678].
Courtney, M.E. The costs of child protection in the context of welfare reform. Future of Children. 1998;8(1):88-103. [pmid: 9676002].
Courtois, C. 1988.
Courtois, C. Assessment and diagnosis. In: Classen, C., ed. Treating Women Molested in Childhood. San Francisco: Jossey-Bass. 1995.
Courtois, C. 1999.
Craddock, S.G.; Rounds-Bryant, J.L.; Flynn, P.M.; and Hubbard, R.L. Characteristics and pretreatment behaviors of clients entering drug abuse treatment: 1969 to 1993. American Journal of Drug and Alcohol Abuse. 1997;23(1):43-59. [pmid: 9048146].
Craine, L.S.; Henson, C.H.; Colliver, J.A.; and MacLean, D.G. Prevalence of a history of sexual abuse among female psychiatric clients in a State hospital system. Hospital and Community Psychiatry. 1988;39:300-304.
Daley, D.C.; Moss, H.B.; and Campbell, F. 1993.
Daro, D., and McCurdy, K. 1991.
Davis, N.; Custer, K.; Bethea-Jackson, G.; Marcey, M.; and Watson, B. 1990.
Davis, S.K. Chemical dependency in women: A description of its effects and outcomes on adequate parenting. Journal of Substance Abuse Treatment. 1990;7:225-232.
De Bellis, M.D. Posttraumatic stress disorder and acute stress disorder. In: Ammerman, R.T., and Hersen, M., eds. Handbook of Prevention and Treatment With Children and Adolescents: Intervention in the Real World Context. New York: John Wiley and Sons. 1997.
De Bellis, M.D., and Putnam, F.W. The psychobiology of childhood maltreatment. Child and Adolescent Psychiatric Clinics of America. 1994;3(4):663-678.
Della Femina, D.; Yeager, C.A.; and Lewis, D.O. Child abuse: Adolescent records vs. adult recall. Child Abuse and Neglect. 1990;14:227-231.
Demaré, D. 1993.
Dembo, R.; Williams, L.; LaVoie, L.; Berry, E.; Getreu, A.; Wish, E.; Schmeidler, J.; and Washburn, M. Physical abuse, sexual victimization, and illicit drug use: Replication of a structural analysis among a new sample of high-risk youths. Violence and Victims. 1989;4(2):121-138. [pmid: 2487129].
DePanfilis, D., and Salus, M.K. A Coordinated Response to Child Abuse and Neglect: A Basic Manual. National Center on Child Abuse and Neglect. DHHS Pub. No. (ACF) 92-30362. Washington, DC: U.S. Government Printing Office. 1992.
Derogatis, L.R. Brief Symptom Inventory (BSI): Administration, Scoring, and Procedures Manual, 2nd ed. Baltimore: Clinical Psychometric Research. 1992.
Derogatis, L.R. Symptom Checklist-90-R (SCL-90-R): Administration, Scoring, and Procedures Manual, 3rd ed. Minneapolis, MN: National Computer Systems. 1994.
Derogatis, L.R.; Lipman, R.; and Covi, L. SCL-90:. An outpatient psychiatric rating scale: Preliminary report. Psychopharmacology Bulletin. 1973;9(17):13-28. [pmid: 4682398].
Derogatis, L.R., and Spencer, P.M. Administration and Procedures: BSI Manual-I, Clinical Psychometric Research. Baltimore: Johns Hopkins University School of Medicine. 1982.
Devore, W., and Schlesinger, E.G. Ethnic-Sensitive Social Work Practice. Columbus, OH: Merrill Publishing Company. 1987.
Deykin, E.Y.; Buka, S.L.; and Zeena, T.H. Depressive illness among chemically dependent adolescents. American Journal of Psychiatry. 1992;149(10):1341-1347. [pmid: 1530070].
Dion, M.R.; Braver, S.L.; Wolchik, S.A.; and Sandler, I.N. Alcohol abuse and psychopathic deviance in noncustodial parents as predictors of child-support payment and visitation. American Journal of Orthopsychiatry. 1997;67:70-79.
Downs, W.R., and Miller, B.A. Inter-generational links between childhood abuse and alcohol-related problems. In: Harrison, L., ed. Alcohol Problems in the Community. London: Routledge. 1996.
Dukma, L.E., and Roosa, M.W. Role of stress and family relationships in mediating problem drinking and fathers' personal adjustment. Journal of Studies on Alcoholism. 1995;56:528-537.
Duncan, F. Prevention issues: Some cautionary notes. In: Hampton, R; Senatore, V.; and Gullotta, T., eds. Substance Abuse, Family Violence, and Child Welfare: Bridging Perspectives. Thousand Oaks, CA: Sage Publications. 1998.
Dunn, G.E.; Paolo, A.M.; Ryan, J.J.; and Van Fleet, J. Dissociative symptoms in a substance abuse population. American Journal of Psychiatry. 1993;150(7):1043-1047. [pmid: 8317574].
Dunn, G.E.; Ryan, J.J.; Paolo, A.M.; and Van Fleet, J. Comorbidity of dissociative disorders among patients with substance use disorders. Psychiatric Services. 1995;46(2):153-156. [pmid: 7712251].
Dutton, D.G. The Batterer: A Psychological Profile. New York: BasicBooks. 1995.
Edwall, G.E., and Hoffman, N.G. Correlates of incest reported by adolescent girls in treatment for substance abuse. In: Walker, L., ed. Handbook on Sexual Abuse of Children: Assessment and Treatment Issues. New York: Springer Publishing. 1987.
Edwall, G.E.; Hoffmann, N.G.; and Harrison, P.A. Psychological correlates of sexual abuse in adolescent girls in chemical dependency treatment. Adolescence. 1989;24(94):279-288. [pmid: 2763895].
Egami, Y.; Ford, D.E.; Greenfield, S.F.; and Crum, R.M. Psychiatric profile and sociodemographic characteristics of adults who report physically abusing or neglecting children. American Journal of Psychiatry. 1996;153:921-928.
Elliott, D.M., and Briere, J. Sexual abuse trauma among professional women: Validating the Trauma Symptom Checklist-40 (TSC-40). Child Abuse and Neglect. 1992;16(3):391-398. [pmid: 1617473].
Erikson, E.H. Identity and the Life Cycle. New York: W.W. Norton. 1980.
Evans, K., and Sullivan, J.M. Treating Addicted Survivors of Trauma. New York: Guilford Press. 1995.
Falsetti, S.A.; Resnick, H.S.; Resnick, P.A.; and Kilpatrick, D. The modified PTSD Symptom Scale: A brief self-report measure of posttraumatic stress disorder. The Behavioral Therapist. 1993;16:161-162.
Famularo, R.; Kinscherff, R.; and Fenton, T. Parental substance abuse and the nature of child maltreatment. Child Abuse and Neglect. 1992;16:475-483.
Farrants, J. The "false memory" debate: A critical review of the research on recovered memories of child sexual abuse. Counseling Psychology Quarterly. 1998;11(3):229-238.
Feig, L. Understanding the problem: The gap between substance abuse programs and child welfare services. In: Hampton, R.L.; Senatore, V.; and Gullota, T.P., eds. Substance Abuse, Family Violence, and Child Welfare: Bridging Perspectives. Thousand Oaks, CA: Sage Publications. 1998.
Feig, L., and McCullough, C. The role of child welfare. In: Haack, M.R., ed. Drug-Dependent Mothers and Their Children. New York: Springer Publishing. 1997.
Felitti, V.J. Long-term medical consequences of incest, rape, and molestation. Southern Medical Journal. 1991;84(3):328-331. [pmid: 2000519].
Felitti, V.J.; Anda, R.F.; Nordenberg, D.; Williamson, D.F.; Spitz, A.M.; Edwards, V.; Koss, M.P.; and Marks, J.S. Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults. The Adverse Childhood Experiences (ACE) Study. American Journal of Preventive Medicine. 1998;14(4):245-258. [pmid: 9635069].
Figley, C. Compassion Fatigue: Coping With Secondary Traumatic Stress Disorder in Those Who Treat the Traumatized. New York: Brunner/Mazel. 1995.
Figueroa, C.; Anda, R.; Whitfield, C.L.; Felitti, V.; Nordenberg, D.; Edwards, V.; Malarcher, A.; and Sharp, D.
Fink, L.A.; Bernstein, D.; Handelsman, L.; Foote, J.; and Lovejoy, M. Initial reliability and validity of the childhood trauma interview: A new multidimensional measure of childhood interpersonal trauma. American Journal of Psychiatry. 1995;152(9):1329-1335. [pmid: 7653689].
Finkelhor, D. The trauma of child sexual abuse: Two models. . Journal of Interpersonal Violence. 1987;2:348-366.
Finkelhor, D. Epidemiological factors in the clinical identification of child sexual abuse. Child Abuse and Neglect. 1993;17(1):67-70. [pmid: 8435788].
Finkelhor, D. Current information on the scope and nature of child sexual abuse. Future of Children. 1994;4(2):31-53. [pmid: 7804768].
Finkelhor, D.; Gelles, R.J.; Hotaling, G.T.; and Strauss, M.A., eds. The Dark Side of Families: Current Family Violence Research. Beverly Hills, CA: Sage Publications. 1983.
Finkelhor, D.; Hotaling, G.; Lewis, I.A.; and Smith, C. Sexual abuse in a national survey of adult men and women: Prevalence, characteristics, and risk factors. Child Abuse and Neglect. 1990;14(1):19-28. [pmid: 2310970].
First, M.B.; Gibbon, M.; Spitzer, R.L.; and Williams, J.B.W. Structured Clinical Interview for DSM-IV Axis I Disorders (SCIDI): Clinician Version. Washington, DC: American Psychiatric Press. 1997.
Foa, E. Posttraumatic Diagnostic Scale Manual. Minneapolis, MN: National Computer Systems. 1996.
Foa, E.; Cashman, L.; Jaycox L.; and Perry, K. The validation of a self-report measure of PTSD: The Posttraumatic Diagnostic Scale (PDS). Psychological Assessment. in press.
Foa, E.B., and Meadows, E.A. Psychosocial treatments for posttraumatic stress disorder: A critical review. Annual Review of Psychology. 1997;48:449-480.
Fontana, V.J., and Besharov, D.J. The Maltreated Child, 4th ed. Springfield, IL: Charles C. Thomas Publishing. 1979.
French, G.D., and Gerbode, F.A. The Traumatic Incident Reduction Workshop, 2nd ed. Menlo Park, CA: IRM Press. 1993.
Funk, J.B. Management of sexual molestation in preschoolers. Clinical Pediatrics (Phila). 1980;19(10):686-688.
Fureman, B.; Parikh, G.; Bragg, A.; and McLellan, A.T. Addiction Severity Index: A Guide to Training and Supervising ASI Interviewers, 5th ed. Philadelphia: University of Pennsylvania and Veterans Administration Center for Studies of Addiction. 1990.
Garbarino, J. The human ecology of child maltreatment. Journal of Marriage and the Family. 1977;39:721-735.
Garbarino, J., and Gilliam, G. Understanding Abusive Families. Lexington, MA: Lexington Books. 1980.
Garbarino, J.; Guttmann, E.; and Seeleya, J. The Psychologically Battered Child. San Francisco: Jossey-Bass. 1986.
Garrity-Rokous, F.E. Punitive legal approaches to the problem of prenatal drug exposure. Infant Mental Health Journal. 1994;15(2):208-237.
General Accounting Office. Juvenile Courts: Reforms Aim To Better Serve Maltreated Children. Pub. No. GAO/HEHS-99-13. Washington, DC: U.S. Government Printing Office. 1999.
Gerard, A.B. Parent-Child Relationship Inventory (PCRI): Manual. Los Angeles: Western Psychological Services. 1994.
Gerstein, D.R.; Johnson, R.A.; Larison, C.L.; Harwood, H.J.; and Fountain, D. Alcohol and Other Drug Treatment for Parents and Welfare Recipients: Outcomes, Costs, and Benefits. Washington, DC: U.S. Department of Health and Human Services. 1997.
Gerstein, D.R.; Johnson, R.A.; Larison, C.L.; Harwood, H.J.; and Fountain, D. Alcohol and Other Drug Treatment for Parents and Welfare Recipients: Outcomes, Costs, and Benefits. Washington, DC: U.S. Department of Health and Human Services. 1998.
Gilliland, B., and James, R. Crisis Intervention Strategies. Pacific Grove, CA: Brooks/Cole. 1988.
Giovannoni, J.M., and Becerra, R.M. Defining Child Abuse. New York: Free Press. 1979.
Giovannoni, J.M., and Billingsley, A. Child neglect among the poor: A study of parental inadequacy in families of three ethnic groups. Child Welfare. 1970;49:196-204.
Glover, N.M.; Janikowski, T.P.; and Benshoff, J.J. Substance abuse and past incest contact: A national perspective. Journal of Substance Abuse Treatment. 1996;13(3):185-193. [pmid: 9017560].
Goerge, R.; Wulczyn, F.; and Harden, A. New comparative insights into States and their foster children. Public Welfare. 1996;54(3):12-25.
Gomes-Schwartz, B.; Horowitz, J.M.; and Sauzier, M. Severity of emotional distress among sexually abused preschool, school-age, and adolescent children. Hospital and Community Psychiatry. 1985;36(5):503-508. [pmid: 4007804].
Gould, J. A psychometric investigation of the standard and short form Beck Depression Inventory. Psychological Reports. 1982;51(3 pt 2):1167-1170.
Greening, T. Posttraumatic stress disorder: An existential-humanistic perspective. In: Krippner, S., and Powers, S.M., eds. Broken Images, Broken Selves: Dissociative Narratives in Clinical Practice. Washington, DC: Brunner/Mazel. 1997.
Grice, D.; Brady, K.; Dustan, L.; Malcolm, R.; and Kilpatrick, D. Sexual and physical assault history and posttraumatic stress disorder in substance-dependent individuals. American Journal of Addictions. 1995;4(4):297-305.
Grosch, W.N., and Olsen, D.C. When Helping Starts To Hurt: A New Look at Burnout Among Psychotherapists. New York: W.W. Norton. 1994.
Gross, A.B., and Keller, H.R. Long-term consequences of childhood physical and psychological maltreatment. Aggressive Behavior. 1992;18:171-185.
Grossman, J., and Schottenfeld, R. Pregnancy and women's issues. In: Kosten, T.R., and Kleber, H.D., eds. Clinician's Guide to Cocaine Addiction: Theory, Research, and Treatment. New York: Guilford Press. 1992.
Gurvitz, T.V.; Shenton, M.E.; and Pitman, R.K. 1995.
Gussman, F.; Stewart, J.; Young, B.; Riney, S.; Abueg, F.; and Blake, D. A multicultural developmental approach for treating trauma. In: Marsella, A.; Friedman, M.; Gerrity, E.; and Scurfield, R., eds. Ethnocultural Aspects of Posttraumatic Stress Disorder: Issues, Research, and Clinical Applications. Washington, DC: American Psychological Association. 1996.
Gutierres, S.E.; Russo, N.F.; and Urbanski, L. Sociocultural and psychological factors in American Indian drug use: Implications for treatment. International Journal of the Addictions. 1994;29(14):1761-1786. [pmid: 7890441].
Gutierres, S.E., and Todd, M. Impact of childhood abuse on treatment outcomes of substance users. Professional Psychology: Research and Practice. 1997;28(4):348-354.
Hammarberg, M. Penn Inventory for Posttraumatic Stress Disorder: Psychometric properties. Psychological Assessment. 1992;4:67-76.
Hammarberg, M. Psychometric review of the Penn Inventory for Post Traumatic Stress Disorder. In: Stamm, B.H., ed. Measurement of Stress, Trauma, and Adaptation. Lutherville, MD: Sidran Press. 1996.
Hansen, M., and Harway, M., eds. Battering and Family Therapy: A Feminist Perspective. Newbury Park, CA: Sage Publications. 1993.
Harrison, J.B., and Morris, L.A. Group therapy for adult male survivors of childhood sexual abuse. In: Andronico, M.P., ed. Men in Groups: Insight, Interventions, and Psychoeducational Work. Washington, DC: American Psychological Association. 1996.
Harrison, P.A.; Hoffman, N.G.; and Edwall, G.E. Differential drug use patterns among sexually abused adolescent girls in treatment for chemical dependency. . International Journal of the Addictions. 1989;24:499-514.
Harrison, P.A.; Hoffman, N.G.; and Edwall, G.E. Sexual abuse correlates: Similarities between male and female adolescents in chemical dependency treatment. . Journal of Adolescent Research. 1989;4(3):385-399.
Hasin, D.S.; Grant, B.F.; Glick, H.R.; and Endicott, J. The Psychiatric Research Interview for Substance and Mental Health Disorders. New York: Department of Research Training, New York State Psychiatric Institute. 1992.
Hasin, D.S.; Trautman, K.D.; Miele, G.M.; Samet, S.; Smith, M.; and Endicott, J. Psychiatric Research Interview for Substance and Mental Disorders (PRISM): Reliability for substance abusers. American Journal of Psychiatry. 1996;153(3):1195-1201. [pmid: 8780425].
Haver, B. Female alcoholics: IV. The relationship between family violence and outcome 3-10 years after treatment. Acta Psychiatrica Scandinavica. 1987;75(5):449-455. [pmid: 3604728].
Hawley, T., and Disney, E. Crack's children: The consequences of maternal cocaine abuse. Social Policy Report: Society for Research in Child Development. 1992;6(4):1-23.
Hayek, M.A. 1980.
Helfer, M.E., and Kempe, R.S., eds. The Battered Child, 5th ed. Chicago: University of Chicago Press. 1997.
Herman, J.L. Trauma and Recovery. New York: BasicBooks. 1992.
Herman, J.L. Sequelae of prolonged and repeated trauma: Evidence for a complex posttraumatic syndrome (DESNOS). In: Davidson, J., and Foa, E., eds. Post-Traumatic Stress Disorder: DSM-IV and Beyond. Washington, DC: American Psychiatric Press. 1993.
Herman, J.L.; Perry, J.C.; and van der Kolk, B.A. Childhood trauma in borderline personality disorder. American Journal of Psychiatry. 1989;146(4):490-495. [pmid: 2929750].
Hien, D.A., and Levin, F.R. Trauma and trauma-related disorders for women on methadone: Prevalence and treatment considerations. . Journal of Psychoactive Drugs. 1994;26(4):421-429. [pmid: 7884604].
Hien, D.A., and Scheier, J. Trauma and short-term outcome for women in detoxification. Journal of Substance Abuse Treatment. 1996;13(3):227-231. [pmid: 9017565].
Holmes, G.R.; Offen, L.; and Waller, G. See no evil, hear no evil, speak no evil: Why do relatively few male victims of childhood sexual abuse receive help for abuse-related issues in adulthood?. Clinical Psychology Review. 1997;17(1):69-88. [pmid: 9125368].
Holmes, W.C., and Slap, G.B. Sexual abuse of boys: Definition, prevalence, correlates, sequelae, and management. JAMA. 1998;280(21):1855-1862. [pmid: 9846781].
Horowitz, M.J. Stress Response Syndromes. New York: Jason Aronson. 1976.
Howard, J. Client-oriented prevention strategies and programs: Pregnant women and their newborns. In: Coombs, R.H., and Ziedonis, D., eds. Handbook on Drug Abuse Prevention: A Comprehensive Strategy to Prevent the Abuse of Alcohol and Other Drugs. Boston: Allyn and Bacon. 1995.
Hunter, M. Abused Boys: The Neglected Victims of Sexual Abuse. Lexington, MA: Lexington Books. 1990.
Hurley, D.L. Incest and the development of alcoholism in adult female survivors. Alcoholism Treatment Quarterly. 1990;7(2):41-56.
Ichiyama, M.A.; Zucker, R.A.; Fitzgerald, H.E.; and Bingham, C.R. Articulating subtype differences in self and relational experience among alcoholic men using structural analysis of social behavior. Journal of Consulting and Clinical Psychology. 1996;64:1245-1254.
Ireland, T., and Widom, C.S. Childhood victimization and risk for alcohol and drug arrests. International Journal of the Addictions. 1994;29(2):235-274. [pmid: 8144278].
Janikowski, T.P., and Glover, N.M. Incest and substance abuse: Implications for treatment professionals. Journal of Substance Abuse Treatment. 1994;11(3):177-183. [pmid: 8072045].
Jarvis, T.J.; Copeland, J.; and Walton, L. Exploring the nature of the relationship between child sexual abuse and substance use among women. Addiction. 1998;93(6):865-875. [pmid: 9744122].
Justice, B., and Duncan, D.F. Physical abuse of children as a public health problem. Public Health Reviews. 1975;4(2):183-200. [pmid: 10297831].
Kahn, M. Between Therapist and Client: The New Relationship. New York: W.H. Freeman and Co. 1991.
Kalichman, S.C. Mandated Reporting of Suspected Child Abuse: Ethics, Law, and Policy. Washington, DC: American Psychological Association. 1993.
Kaufman, J., and Zigler, E. Do abused children become abusive parents?. American Journal of Orthopsychiatry. 1987;57(2):186-192. [pmid: 3296775].
Kearney, M.; Murphy, S.; and Rosenbaum, M. Mothering on crack cocaine: A grounded theory analysis. Social Science and Medicine. 1994;38(2):351-361. [pmid: 8140462].
Kempe, C.H., and Helfer, R.E. Helping the Battered Child and His Family. Philadelphia: Lippincott. 1972.
Killeen, T.K.; Brady, K.T.; and Thevos, A. Addiction severity, psychopathology and treatment compliance in cocaine-dependent mothers. Journal of Addictive Diseases. 1995;14:75-84.
Klerman, G. L. Interpersonal Psychotherapy of Depression. New York: BasicBooks. 1984.
Klerman, G.L., and Weissman, M.M., eds. New Applications of Interpersonal Psychotherapy. Washington, DC: American Psychiatric Press. 1993.
Kovach, J.A. 1983.
Krinsley, K.E. Psychometric review of the Evaluation of Lifetime Stressors (ELS) questionnaire and interview. In: Stamm, B.H., ed. Measurement of Stress, Trauma, and Adaptation. Lutherville, MD: Sidran Press. 1996.
Krinsley, K.E.; Brief, D.J.; Weathers, F.W.; and Steinberg, H.R. 1994.
Krinsley, K.E.; Gallagher, J.H.; Weathers, F.W.; Kaloupek, D.G.; and Vielhauer, M. 1997.
Krinsley, K.E.; Young, L.S.; Weathers, F.W.; Brief, D.J.; and Kelley, J.M. 1992.
Kroll, P.D.; Stock, D.F.; and James, M.E. The behavior of adult alcoholic men abused as children. Journal of Nervous and Mental Disease. 1985;173(11):689-693. [pmid: 4056784].
Kropenske, V., and Howard, J. Protecting Children in Substance-Abusing Families: The User Manual Series. Washington, DC: U.S. Department of Health and Human Services, National Center on Child Abuse and Neglect. 1994.
Krugman, S. Men's shame and trauma in therapy. In: Pollack, W.S., and Levant, R.F., eds. New Psychotherapy for Men. New York: John Wiley and Sons. 1998.
Kufeldt, K., and Nimmo, M. Youth on the street: Abuse and neglect in the eighties. Child Abuse and Neglect. 1987;11:531-543.
Kumpfer, K.L.; Molraard, V.; and Spoth, R. The Strengthening Families Program for the prevention of delinquency and drug use. In: Peters, R.D., and McMahon, R.J., eds. Preventing Childhood Disorders, Substance Abuse, and Delinquency. Thousand Oaks, CA: Sage Publications. 1996.
Kuyken, W., and Brewin, C.R. Intrusive memories of childhood abuse during depressive episodes. Behavior Research and Therapy. 1994;32:525-528.
LaCoursiere, R.B. Diverse motives for fictitious post-traumatic stress disorder. Journal of Traumatic Stress. 1993;6(1):141-149.
Lammers, S.M.; Schippers, G.M.; and van der Staak, C.P. 1995.
Landrine, H., and Klonoff, E.A. The schedule of racist events: A measure of racial discrimination and a study of its negative physical and mental health consequences. . Journal of Black Psychology. 1996;22:144-168.
Landry, M. Understanding Drugs of Abuse: The Processes of Addiction, Treatment, and Recovery. Washington, DC: American Psychiatric Press. 1994.
Langeland, W., and Hartgers, C. Child sexual and physical abuse and alcoholism: A review. Journal of Studies on Alcohol. 1998;59(3):336-348. [pmid: 9598715].
Leber, W.R.; Jenkins, R.L.; and Parsons, O.A. Recovery of visual-spatial learning and memory in chronic alcoholics. Journal of Clinical Psychology. 1981;37(1):192-197. [pmid: 7204599].
Legal Action Center. Confidentiality: A Guide to the Federal Laws and Regulations. New York: Legal Action Center, 1995.
Lerner, H.G. Women in Therapy: Devaluation, Anger, Aggression, Depression, Self-Sacrifice, Mothering, Mother Blaming, Self-Betrayal, Sex-Role Stereotypes, Dependency, Work and Success Inhibitions. New York: Jason Aronson. 1988.
Levey, S.J., and Rutter, E. Children of Drug Abusers. New York: Lexington Books. 1992.
Linehan, M.M. Cognitive-Behavioral Treatment of Borderline Personality Disorder. New York: Guilford Press. 1993.
Linehan, M.M. Skills Training Manual for Treating Borderline Personality Disorder. New York: Guilford Press. 1993.
Loftus, E.F. The reality of repressed memories. American Psychologist. 1993;48(5):518-537. [pmid: 8507050].
Loftus, E.F. Memory distortion and false memory creation. Bulletin of the American Academy of Psychiatry and the Law. 1996;24(3):281-295. [pmid: 8889130].
Luthar, S.S., and Suchman, N.E. Developmentally informed parenting interventions: The Relational Psychotherapy Mothers' Group. In: Cicchetti, D., and Toth, S., eds. Rochester Symposium on Developmental Psychopathology. Vol. 10, Developmental Approaches to Prevention and Intervention. Rochester, NY: University of Rochester Press. 1999.
Luthar, S.S., and Suchman, N.E. Relational Psychotherapy Mothers' Group: A developmentally informed intervention for at-risk mothers. Development and Psychopathology. in press.
Luthar, S.S., and Walsh, K.G. Treatment needs of drug-addicted mothers. Integrated parenting psychotherapy interventions. . Journal of Substance Abuse Treatment. 1995;12(5):341-348. [pmid: 8583517].
Mackay, P.W., and Marlatt, G.A. Maintaining sobriety: Stopping is starting. . International Journal of the Addictions. 1990;25:1257-1276. 1991.
MacMillan, H.L.; Fleming, J.E.; Trocmé, N.; Boyle, M.H.; Wong, M.; Racine, Y.A.; Beardslee, W.R.; and Offord, D.R. Prevalence of child physical and sexual abuse in the community: Results from the Ontario Health Supplement. JAMA. 1997;278:131-135.
Magura, S., and Laudet, A.B. Parental substance abuse and child maltreatment: Review and implications for intervention. Children and Youth Services Review. 1996;18(3):193-220.
Malinosky-Rummell, R., and Hansen, D.J. Long-term consequences of childhood physical abuse. Psychological Bulletin. 1993;114(1):68-79. [pmid: 8346329].
Manson, S.M. Cross-cultural and multiethnic assessment of trauma. In: Wilson, W.J., and Keane, T.M., eds. Assessing Psychological Trauma and PTSD. New York: Guilford Press. 1997.
Marlatt, G.A., and Gordon, J.R., eds. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors. New York: Guilford Press. 1985.
Mayes, L.C.; Feldman, R.; Granger, R.H.; Haynes, O.M.; Bornstein, M.H.; and Schottenfeld, R. The effects of polydrug use with and without cocaine on mother-infant interaction at 3 and 6 months. Infant Behavior and Development. 1997;20(4):489-502.
McClain, P.W.; Sack, J.J.; Froehlke, R.G.; and Ewigman, B.G. Estimates of fatal child abuse and neglect, United States, 1979 through 1988. Pediatrics. 1993;91:338-343.
McCord, J. A forty-year perspective on effects of child abuse and neglect. Child Abuse and Neglect. 1983;7:265-270.
McCurdy, K., and Daro, D. Current Trends in Child Abuse Reporting and Fatalities: The Results of the 1993 Annual Fifty State Survey. Chicago: National Committee for Prevention of Child Abuse. 1994.
McGee, R.A., and Wolfe, D.A. Psychological maltreatment: Toward an operational definition. Development and Psychopathology. 1991;3:3-18.
McLellan, A.T.; Parikh, G.; Bragg, A.; Cacciola, J.; Fureman, B.; and Incmikoski, R. Addiction Severity Index: Administration Manual. Philadelphia: University of Pennsylvania and Veterans Administration Center for Studies of Addiction. 1990.
McMahon, T.J., and Luthar, S.S. Bridging the gap for children as their parents enter substance abuse treatment. In: Hampton, R.L.; Senatore, V.; and Gullota, T.P., eds. Substance Abuse, Family Violence, and Child Welfare: Bridging Perspectives. Thousand Oaks, CA: Sage Publications. 1998.
McNair, D.M.; Lorr, M.; and Droppleman, L.F. EdITS Manual for the Profile of Mood States. San Diego, CA: Educational and Industrial Testing Service. 1992.
Melton, G.B.; Goodman, G.S.; Kalichman, S.C.; Levine, M.; Saywitz, K.J.; and Koocher, G.P. Empirical research on child maltreatment and the law. Journal of Clinical Child Psychology. 1995;24(Suppl):47-77.
Metsch, L.R.; Rivers, J.E.; Miller, M.; Bohs, R.; McCoy, C.B.; Morrow, C.J.; Bandstra, E.S.; Jackson, V.; and Gissen, M. Implementation of a family-centered treatment program for substance-abusing women and their children: Barriers and resolutions. Journal of Psychoactive Drugs. 1995;27(1):73-83. [pmid: 7602443].
Miller, B.A., and Downs, W.R. Violent victimization among women with alcohol problems. Recent Developments in Alcoholism. 1995;12:81-101.
Miller, B.A.; Downs, W.R.; and Testa, M. Interrelationships between victimization experiences and women's alcohol use. Journal of Studies on Alcohol. 1993;11:109-117.
Miller, B.A.; Maguin, E.; and Downs, W.R. Alcohol, drugs, and violence in children's lives. Recent Developments in Alcoholism. 1997;13:357-385.
Miller, W.R.; Brown, J.M.; Simpson, T.L.; Handmaker, N.S.; Bien, T.H.; Luckie, L.F.; Montgomery, H.A.; Hester, R.K.; and Tonigan, J.S. What works? A methodological analysis of the alcohol treatment outcome literature. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches, 2nd ed. Boston: Allyn and Bacon. 1995.
Miller, W.R., and Sovereign, R.G. The Check-up: A model for early intervention in addictive behaviors. In: Loberg, T.; Miller, W.R.; Nathan, P.E.; and Marlatt, G.A., eds. Addictive Behaviors: Prevention and Early Intervention. Amsterdam: Swets and Zeitlinger. 1989.
Miller, W.R.; Taylor, C.A.; and West, J.C. Focused versus broad-spectrum behavior therapy for problem drinkers. Journal of Consulting and Clinical Psychology. 1980;48(5):590-601. [pmid: 7410657].
Miller, W.R.; Tonigan, J.S.; and Longabaugh, R. The Drinker Inventory of Consequences (DrInC): An Instrument for Assessing Adverse Consequences of Alcohol Abuse. Test Manual, Project MATCH Monograph Series, Vol. 4. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism. 1995.
Mokuau, N., ed. Handbook of Social Services for Asian and Pacific Islanders. New York: Greenwood Press. 1991.
Mumm, A.M.; Olsen, L.J.; and Allen, D. Families affected by substance abuse: Implications for generalist social work practice. Families in Society. 1998;79(4):384-394.
Najavits, L.M.; Weiss, R.D.; Reif, S.; Gastfriend, D.R.; Siqueland, L.; Barber, J.P.; Butler, S.F.; Thase, M.; and Blaine, J. The addiction severity index as a screen for trauma and posttraumatic stress disorder. Journal of Studies on Alcohol. 1998;59(1):56-62. [pmid: 9498316].
National Association of Alcoholism and Drug Abuse Counselors (NAADAC). Counselors' Ethical Standards of Alcoholism and Drug Abuse Counselors. http://www.naadac.org/ethics.htm [Accessed Sept. 9. 1999.
National Center on Child Abuse and Neglect. Child Maltreatment 1995: Reports From the States to the National Center on Child Abuse and Neglect. Washington, DC: U.S. Government Printing Office. 1997.
National Center on Child Abuse and Neglect. National Child Abuse and Neglect Statistical Fact Sheet. http://www.calib.com.80/nccanch/pubs/statinfo/stats.htm [Accessed July 15. 1999.
National Institute on Drug Abuse. Assessing Client Needs Using the Addiction Severity Index: Resource Manual. NIH Pub. No. 93-3620. Rockville, MD: National Institute on Drug Abuse. 1993.
National Institute on Drug Abuse. Substance Abuse Among Women and Parents. Washington, DC: U.S. Government Printing Office. 1994.
National Research Council. Understanding Child Abuse and Neglect. Washington, DC: National Academy Press. 1993.
Neisen, J.H., and Sandall, H. Alcohol and other drug abuse in a gay/lesbian population: Related to victimization?. Journal of Psychology and Human Sexuality. 1990;3:151-168.
Neumann, D.A.; Houskamp, B.M.; Pollock, V.E.; and Briere, J. The long-term sequelae of childhood sexual abuse in women: A meta-analytic review. Child Maltreatment. 1996;1:6-16.
Newman, E.; Kaloupek, D.G.; and Keane, T.M. Assessment of posttraumatic stress disorder in clinical and research settings. In: van der Kolk, B.A.; McFarlane, A.C.; and Weisaeth, L., eds. Traumatic Stress: The Effects of Overwhelming Experiences on Mind, Body, and Society. New York: Guilford Press. 1996.
Ney, P.G.; Fung, T.; and Wickett, A.R. Child neglect: The precursor to child abuse. . Pre- and Perinatal Psychology Journal. 1993;8:95-112.
Ney, P.G.; Fung, T.; and Wickett, A.R. The worst combinations of child abuse and neglect. Child Abuse and Neglect. 1994;18(9):705-714. [pmid: 8000901].
Nyman, G.; Harbin, H.; Book, J.; Wiegand, D.; Lizanich-Aro, S.; Krajewski, T.; Yuhas, M.; and Shoffeitt, P. Green Spring criteria for medical necessity of outpatient treatment and its use in a mental health utilization review program. Quality Assurance Utilization Review. 1992;7(2):65-69.
Olsen, L.J. Services for substance abuse-affected families: The Project Connect experience. Child and Adolescent Social Work Journal. 1995;12(3):183-195.
Ostendorf, C.G. "Alcohol Abuse: An Alternative to Dissociation as a Psychological Coping Strategy of Adult Female Incest Survivors." Ph.D. dissertation, University of Wisconsin, Milwaukee, 1995. Abstract in. Dissertation Abstracts International. 1995;57(2):591-A.
Ouimette, P.C.; Wolfe, J.; and Chrestman, K.R. Characteristics of posttraumatic stress disorder-Alcohol abuse comorbidity in women. Journal of Substance Abuse. 1996;8(3):335-346. [pmid: 8934438].
Palmer, J.A.; Palmer, L.K.; Williamson, D.; Michiels, K.; and Thigpen, B. Childhood abuse as a factor in attrition from drug rehabilitation. Psychological Reports. 1995;76(3 Pt 1):879-882.
Paone, D.; Chavkin, W.; Willets, I.; Friedmann, P.; and des Jarlais, D. The impact of sexual abuse: Implications for drug treatment. Journal of Women's Health. 1992;1:149-153.
Paradise, J.E.; Rose, L.; Sleeper, L.A.; and Nathanson, M. Behavior, family function, school performance, and predictors of persistent disturbance in sexually abused children. Pediatrics. 1994;93(3):452-459. [pmid: 8115205].
Pearce, E., and Lovejoy, F. The development and testing of a diagnostic scale for incest survivors. Journal of Social Psychology. 1994;134(5):677-679. [pmid: 7807980].
Pearce, E., and Lovejoy, F. Detecting a history of childhood sexual experiences among women substance abusers. Journal of Substance Abuse Treatment. 1995;12:283-287.
Pearlman, L.A., and Saakvitne,. K.W. Trauma and the Therapist: Countertransference and Vicarious Traumatization in Psychotherapy With Incest Survivors. New York: W.W. Norton. 1995.
Peck, S. The Road Less Traveled. New York: Simon and Schuster. 1981.
Peterson, L.; Gable, S.; and Saldana, L. Treatment of maternal addiction to prevent child abuse and neglect. Addictive Behaviors. 1996;21(6):789-801. [pmid: 8904944].
Peterson, M.S., and Urquiza, A.J. The Role of Mental Health Professionals in the Prevention and Treatment of Child Abuse and Neglect. Washington, DC: National Center on Child Abuse and Neglect, Department of Health and Human Services. 1993.
Polansky, N.; Chalmers, M.A.; Buttenwieser, E.; and Williams, D.P. Damaged Parents: An Anatomy of Child Neglect. Chicago: University of Chicago Press. 1981.
Pollock, C., and Steele, B. A therapeutic approach to the parents. In: Kempe, C.H., and Helfer, R.E., eds. Helping the Battered Child and His Family. Philadelphia: Lippincott. 1972.
Pollock, V.E.; Briere, J.; Schneider, L.; Knop, J.; Mednick, S.A.; and Goodwin, D.W. Childhood antecedents of antisocial behavior: Parental alcoholism and physical abusiveness. American Journal of Psychiatry. 1990;147(10):1290-1293. [pmid: 2399994].
Polusny, M.A., and Follette, V.M. Long-term correlates of child sexual abuse: Theory and review of the empirical literature. Applied and Preventive Psychology. 1995;4(3):143-166.
Pope, H.G., and Hudson, J.I. Is childhood sexual abuse a risk factor for bulimia nervosa?. American Journal of Psychiatry. 1992;149(4):455-463. [pmid: 1554029].
Potter-Efron, R.T., and Potter-Efron, P.S. Anger, Alcoholism, and Addiction: Treating Individuals, Couples and Families. New York: W.W. Norton. 1991.
Pribor, E.F., and Dinwiddie, S.H. Psychiatric correlates of incest in childhood. American Journal of Psychiatry. 1992;149:52-56.
Price, R.K.; Breslau, N.; Chilcoat, H.D.; Triffleman, E.; True, W.R.; and Kosten, T.R. Symposium XIV: PTSD and substance abuse: Epidemiology, genetics and neurobiology. In: Leshner, A.I., ed. Problems of Drug Dependence 1997: Proceedings from the 59th Annual Scientific Meeting of the College on Problems of Drug Dependence. NIDA Research Monograph Series, Number 178. NIH Pub. No. 98-4305. Rockville, MD: National Institute on Drug Abuse. 1998.
Putnam, F.W. Dissociation in Children and Adolescents: A Developmental Perspective. New York: Guilford Press. 1997.
Rabasca, L. APA pursues "test cases" to set legal precedents. APA Monitor. 1998;29(11). http://www.apa.org/monitor/nov98/mc.html [Accessed Jan. 27, 1999].
Rausch, K., and Knutson, J.F. The self-report of personal punitive childhood experiences and those of siblings. Child Abuse and Neglect. 1991;15(1-2):29-36.
Rauch, S.L.; van der Kolk, B.A.; Fisler, R.E.; Alpert, N.M.; Orr, S.P.; Savage, C.R.; Fischman, A.J.; Jenike, M.A.; and Pitman, R.K. A symptom provocation study of posttraumatic stress disorder using positron emission tomography and script-driven imagery. Archives of General Psychiatry. 1996;53(5):380-387. [pmid: 8624181].
Ray, O., and Ksir, C. Drugs, Society, and Human Behavior. St. Louis, MO: Mosby. 1996.
Reed, B.G. Linkages: Battering, sexual assault, incest, child sexual abuse, teen pregnancy, dropping out of school, and the drug and alcohol connection. In: Roth, P., ed. Alcohol and Drugs Are Women's Issues. Vol. 1. A Review of Issues. Metuchen, NJ: Scarecrow Press. 1991.
Reed, R.J.; Grant, I.; and Rourke, S.B. Long-term abstinent alcoholics have normal memory. Alcoholism, Clinical and Experimental Research. 1992;16(4):677-683.
Reid, J.; Macchetto, P.; and Foster, S. No Safe Haven: Children of Substance-Abusing Parents. New York: National Center on Addiction and Substance Abuse at Columbia University. 1999.
Resnick, H.S. Psychometric review of national women's study (NWS) event history-PTSD Module. In: Stamm, B.H., ed. Measurement of Stress, Trauma, and Adaptation. Lutherville, MD: Sidran Press. 1996.
Resnick, H.S. Psychometric review of trauma assessment for adults (TAA). In: Stamm, B.H., ed. Measurement of Stress, Trauma, and Adaptation. Lutherville, MD: Sidran Press. 1996.
Resnick, H.S.; Falsetti, S.A.; Kilpatrick, D.G.; and Freedy, J.R. Assessment of rape and other civilian trauma-related post-traumatic stress disorder: Emphasis on assessment of potentially traumatic events. In: Miller, T.W., ed. Stressful Life Events. Madison, WI: International Universities Press. 1996.
Ripple, L. Motivation, Capacity and Opportunity: Studies in Casework Theory and Practice. Chicago: University of Chicago Press. 1964.
Robins, L.; Helzer, J.E.; Croughan, J; and Ratcliff, K.S. National Institute of Mental Health Diagnostic Interview Schedule: Its history, characteristics, and validity. Archives of General Psychiatry. 1981;38(4):381-389. [pmid: 6260053].
Rodning, C.; Beckwith, L.; and Howard, J. Prenatal exposure to drugs: Behavioral distortions reflecting CNS impairment?. Neurotoxicology. 1989;10(3):629-634. [pmid: 2626221].
Roesler, T.A., and Dafler, C.E. Chemical dissociation in adults sexually victimized as children: Alcohol and drug use in adult survivors. Journal of Substance Abuse Treatment. 1993;10(6):537-543. [pmid: 8308938].
Rogers, C.R. A theory of therapy, personality, and interpersonal relationships as developed in the client-centered framework. In: Koch, S., ed. Psychology: The Study of a Science. Vol. 3. Formulations of the Person and the Social Context. New York: McGraw-Hill. 1959.
Rohner, R.P. Handbook for the Study of Parental Acceptance and Rejection, rev. ed. Storrs, CT: Center for the Study of Parental Acceptance and Rejection, University of Connecticut. 1990.
Rohsenow, D.J.; Corbett, R.; and Devine, D. Molested as children: A hidden contribution to substance abuse?. Journal of Substance Abuse Treatment. 1988;5:13-18.
Rose, S.M. Acknowledging abuse backgrounds of intensive case management clients. Community Mental Health Journal. 1991;27(4):255-263. [pmid: 1864075].
Ross, C.A.; Anderson, G.; Heber, S.; and Norton, G.R. Dissociation and abuse among multiple personality clients, prostitutes, and exotic dancers. Hospital and Community Psychiatry. 1990;41(3):328-330. [pmid: 2312084].
Rounsaville, B.J.; Glazer, W.; Wilber, C.H.; Weissman, M.M.; and Kleber, H.D. Short-term interpersonal psychotherapy in methadone-maintained opiate addicts. Archives of General Psychiatry. 1983;40(6):629-636. [pmid: 6342563].
Rowan, A.B., and Foy, D.W. PTSD in child sexual abuse. Journal of Traumatic Stress. 1993;6: 3-20.
Rowan, A.B.; Foy, D.W.; Rodriguez, N.; and Ryan, S. Posttraumatic stress disorder in a clinical sample of adults sexually abused as children. Child Abuse and Neglect. 1994;18(1):51-61. [pmid: 8124598].
Rubin, J. Practical suggestions for working with substance abusing families. . The Source. 1998;8(2):16-17.
Russell, D.E. The incidence and prevalence of intrafamilial and extrafamilial sexual abuse of female children. Child Abuse and Neglect. 1983;7:133-146.
Ryan, V., and Popour, J. Five Year Women's Plan. Capital Area Substance Abuse Commission for the Office of Substance Abuse, Michigan Department of Health. Lansing, MI: Michigan Department of Health. 1983.
Saakvitne, K.W., and Gamble, S. Risking Connection: Responding Helpfully to the Needs of Trauma Survivors. Lutherville, MD: Sidran Press, in press.
Satir, V. Peoplemaking. Palo Alto, CA: Science and Behavior Books. 1972.
Satir, V., and Baldwin, M. Satir Step by Step: A Guide to Creating Change in Families. Palo Alto, CA: Science and Behavior Books. 1983.
Schene, P.A. Past, present, and future roles of child protective services. Future of Children. 1998;8(1):23-38. [pmid: 9675998].
Sedlak, A.J., and Broadhurst, D.D. The Third National Incidence Study of Child Abuse and Neglect. National Center on Child Abuse and Neglect. Washington, DC: U.S. Government Printing Office. 1996.
Shaver, P.R.; Goodman, G.S.; Rosenberg, M.S.; and Orcutt, H. The search for a definition of psychological maltreatment. Development and Psychopathology. 1991;3:79-86.
Sheehan, D.V.; Lecrubier, Y.; Janavs, J.; Knapp, E.; Weiller, E.; Amorim, P.; Lepine, J.P.; Sheehan, M.F.; Baker, R.R.; and Sheehan, K.H. Mini International Neuropsychiatric Interview. Tampa, FL: University of South Florida Institute for Research in Psychiatry. 1994.
Sheehan, D.V.; Lecrubier, Y.; Sheehan, K.H.; Janavs, J.; Weiller, E.; Keskiner, A.; Schinka, J.; Knapp, E.; Sheehan, M.F.; and Dunbar, G.C. 1996.
Sheehan, P.L. Treating intimacy issues of traumatized people. In: Williams, M.B., and Sommer, J.F., Jr., eds. Handbook of Post-Traumatic Therapy. Westport, CT: Greenwood Press. 1994.
Sheridan, M.J. A proposed intergenerational model of substance abuse, family functioning, and abuse/neglect. Child Abuse and Neglect. 1995;19(5): 519-530.
Silverman, A.B.; Reinherz, H.Z.; and Giaconia, R.M. The long-term sequelae of child and adolescent abuse: A longitudinal community study. Child Abuse and Neglect. 1996;20(8):709-723. [pmid: 8866117].
Simpson, T.L.
Simpson, T.L., and Miller, W.R.
Simpson, T.L.; Westerberg, V.; Little, L.M.; and Trujillo, M. Screening for childhood physical and sexual abuse among outpatient substance abusers. Journal of Substance Abuse Treatment. 1994;11(4):347-358. [pmid: 7966505].
Singer, M.I.; Petchers, M.K.; and Hussey, D. The relationship between sexual abuse and substance abuse among psychiatrically hospitalized adolescents. Child Abuse and Neglect. 1989;13(3):319-325. [pmid: 2776040].
Spitzer, R.L., and Endicott, J. Schedule for Affective Disorders and Schizophrenia SADS, 3rd ed. New York: New York State Psychiatric Institute. 1978.
Springer, C. Female adolescents, the experience of violence, and the meaning of the body. Clinical Social Work Journal. 1997;25:281-296.
Stamm, B.H. Secondary Traumatic Stress: Self-Care Issues for Clinicians, Researchers, and Educators, 2nd ed. Lutherville, MD: Sidran Press. 1999.
Steele, B. Reflections on the therapy of those who maltreat children. In: Helfer, R.E., and Kempe, R.S., eds. The Battered Child, 4th ed. Chicago: University of Chicago Press. 1987.
Stein, M.B.; Koveroa, C.; Hanna, C.; Torchia, M.G.; and McClarty, B. Hippocampal volume in women victimized by childhood sexual abuse. Psychological Medicine. 1997;27(4):951-959. [pmid: 9234472].
Steinberg, K.L.; Levine, M.; and Doueck, H.J. Effects of legally mandated child-abuse reports on the therapeutic relationship: A survey of psychotherapists. American Journal of Orthopsychiatry. 1997;67(1):112-122. [pmid: 9034027].
Steinglass, P. The Alcoholic Family. New York: BasicBooks. 1987.
Stephenson, M.D. "Evaluating the Impact of Incest on the Recovery of Alcohol/Drug Dependent Women in Residential Care." Ph.D. dissertation, University of Nebraska, 1990. Abstract in. Dissertation Abstracts International. 1990;51(3):1514-B.
Stewart, S.H. Alcohol abuse in individuals exposed to trauma: A critical review. Psychological Bulletin. 1996;120(1):83-112. [pmid: 8711018].
Straton, D. Catharsis reconsidered. Australian and New Zealand Journal of Psychiatry. 1990;24:543-551.
Straus, M.A., and Gelles, R.J. How violent are American families? Estimates from the National Family Violence Survey and other studies. In: Straus, M.A., and Gelles, R.J., eds. Physical Violence in American Families: Risk Factors and Adaptations to Violence in 8,145 Families. New Brunswick, NJ: Transaction Publishers. 1990.
Straus, M.A., and Kantor, G.K. Corporal punishment of adolescents by parents: A risk factor in the epidemiology of depression, suicide, alcohol abuse, child abuse, and wife beating. Adolescence. 1994;29:543-561.
Substance Abuse and Mental Health Services Administration. Preliminary Estimates From the 1995 National Household Survey on Drug Abuse. Advance Report No. 18, August. 1996.
Sue, D.W.; Arredondo, P.; and McDavis, R.J. Multicultural counseling competencies and standards: A call to the profession. Journal of Counseling and Development. 1992;70(4):477-486.
Sullivan, R.A.; Schaefer, J.L.; and Goldstein, F.L. Child molestation. American Family Physician. 1979;19(3):127-132. [pmid: 425865].
Surrey, J. The "self-in-relation": A theory of women's development. Work in Progress. 1985;No. 13:1-10.
Swan, N. Exploring the role of child abuse in later drug use. NIDA Notes. 1998;13(2):1-4.
Swift, W.; Copeland, J.; and Hall, W. Characteristics of women with alcohol and other drug problems: Findings of an Australian national survey. Addiction. 1996;91(8):1141-1150. [pmid: 8828242].
Thompson, V.L. Perceived experiences of racism as stressful life events. . Community Mental Health Journal. 1996;32:223-233.
Traux, C.B., and Carkhoff, R.R. Toward Effective Counseling and Psychotherapy: Training and Practice. Chicago: Aldine Publishing. 1967.
Trickett, P.K., and McBride-Chang, C. The developmental impact of different forms of child abuse and neglect. Developmental Review. 1995;15(3):311-337.
Trickett, P.K., and Putnam, F.W. Impact of child sexual abuse on females: Toward a developmental, psychobiological integration. Psychological Science. 1993;4:81-87.
Tunving, K., and Nilsson, K. Young female drug addicts in treatment: A 12 year perspective. Journal of Drug Issues. 1985;15(3):367-382.
Turkus, J.A., and Cohen, B.M. The Spectrum of Dissociative Disorders: An Overview of Diagnosis and Treatment. http:www.voiceofwomen.com/centerarticle.html [Accessed Oct. 14. 1998.
Tyler, R.; Howard, J.; Espinosa, M.; and Doakes, S.S. Placement with substance-abusing mothers vs. placement with other relatives: Infant outcomes. Child Abuse and Neglect. 1997;21(4):337-349. [pmid: 9134263].
U.S. Department of Health and Human Services. Blending Perspectives and Building Common Ground: A Report to Congress on Substance Abuse and Child Protection. Washington, DC: U.S. Government Printing Office. 1999.
U.S. Department of Justice. Federal Bureau of Prisons. Triad Drug Treatment Evaluation--Six-Month Report: Executive Summary (. 1998.
Valentine, P.V. Traumatic incident reduction: A review of a new intervention. Journal of Family Psychotherapy. 1995;6(2):73-78.
Valentine, P.V. Traumatic incident reduction: Treatment of trauma-related symptoms in incarcerated females. Proceedings of the Tenth National Symposium on Doctoral Research in Social Work. Columbus, OH: Ohio State University College of Social Work. 1998.
Valentine, P.V. Traumatic Incident Reduction (TIR): Brief, intense treatment for battered women. Crisis Intervention and Time-Limited Treatment. 5(2): in press.
Valentine, P.V., and Smith, T.E. A qualitative study of client perceptions of Traumatic Incident Reduction (TIR): A brief trauma treatment. Crisis Intervention and Time-Limited Treatment. 1998;4(1): 1-12.
Valentine, P.V., and Smith, T.E. Evaluating Traumatic Incident Reduction (TIR) Therapy with female inmates: A randomized controlled clinical trial. Research on Social Work Practice. in press.
Van Dam, C.; Halliday, L.; and Bates, C. The occurrence of sexual abuse in a small community. Canadian Journal of Community Mental Health. 1985;4(1):105-111.
van der Kolk, B.A. The psychobiology of the trauma response: Hyperarousal, constriction, and addiction to traumatic reexposure. In: van der Kolk, B.A., ed. Psychological Trauma. Washington, DC: American Psychiatric Press. 1987.
van der Kolk, B.A. The body keeps the score: Approaches to the psychobiology of posttraumatic stress disorder. In: van der Kolk, B.A.; McFarlane, A.C.; and Weisaeth, L., eds. Traumatic Stress: The Effects of Overwhelming Experience on Mind, Body, and Society. New York: Guilford Press. 1996.
Van Hasselt, V.B.; Ammerman, R.T.; Glancy, L.J.; and Bukstein, O.G. Maltreatment in psychiatrically hospitalized dually diagnosed adolescent substance abusers. Journal of the American Academy of Child and Adolescent Psychiatry. 1992;31:868-874.
Wald, M.S. Defining psychological maltreatment: The relationship between questions and answers. Development and Psychopathology. 1991;3:111-118.
Wald, R.; Harvey, S.M.; and Hibbard, J. A treatment model for women substance users. International Journal of the Addictions. 1995;30(7):881-888. [pmid: 7558476].
Walker, C.A. Adult children of alcoholics: Measuring the personality characteristics of autonomy, inferiority and intimacy. Dissertation Abstracts International 55(3):474-A, 1994.
Walker, C.; Zangrillo, P.; and Smith J. Parental Drug Abuse and African American Children in Foster Care: Issues and Study Findings. Washington, DC: National Black Child Development Institute. 1991.
Wallen, J., and Berman, K. Possible indicators of childhood sexual abuse for individuals in substance abuse treatment. . Journal of Child Sexual Abuse. 1992;1(3):63-74.
Wand, G.S.; Mangold, D.; El Deiry, S.; McCaul, M.E.; and Hoover, D. Family history of alcoholism and hypothalamic opioidergic activity. Archives of General Psychiatry. 1998;55(12):1114-1119. [pmid: 9862555].
Wang, C.T., and Daro, D. Current Trends in Child Abuse Reporting and Fatalities: The Results of the 1997 Annual Fifty State Survey. Chicago: National Committee to Prevent Child Abuse. 1998.
Washton, A.M. Structured outpatient group therapy. In: Lowinson, J.H.; Ruiz, P.; Millman, R.B.; and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook, 3rd ed. Baltimore: Williams & Wilkins. 1997.
Watson, H., and Levine, M. Psychotherapy and mandated reporting of child abuse. American Journal of Orthopsychiatry. 1989;59:246-256.
Weathers, F.W., and Litz, B.T. Psychometric properties of the clinician-administered PTSD scales. PTSD Research Quarterly. 1994;5:2-6.
Wedenoja, M., and Reed, B. Women's groups as a form of intervention for drug dependent women. In: Beschner, G.M.; Reed, B.G.; and Mondanaro, J., eds. Treatment Services for Drug Dependent Women. Vol. II. NIDA Treatment Research Monograph Series. DHHS Pub. No. (ADM) 82-1219. Rockville, MD: National Institute on Drug Abuse. 1982.
Wegsheider, S. Another Chance: Hope and Health for the Alcoholic Family. Palo Alto, CA: Science and Behavior Books. 1981.
Wessells, D.T., Jr., ed. Professional Burnout in Medicine and the Helping Professions. New York: Haworth Press. 1989.
Whipple, E.E., and Richey, C.A. Crossing the line from physical discipline to child abuse: How much is too much?. Child Abuse and Neglect. 1997;21:431-444.
Whitfield, C.L. Children of alcoholics: Treatment issues. In: Foster, W.D.; DeLuca, J.R.; and O'Gorman, P.A., eds. Services for Children of Alcoholics. NIAAA Research Monograph Series, Number 4. DHHS Pub. No. (ADM) 81-1007. Silver Spring, MD: National Institute on Alcohol Abuse and Alcoholism. 1981.
Whitfield, C.L. Stress management and spirituality during recovery: A transpersonal approach. Alcoholism Treatment Quarterly. 1984;1(1):3-54.
Whitfield, C.L. Healing the Child Within: Discovery and Recovery for Adult Children of Dysfunctional Families. Pompano Beach, FL: Health Communications. 1987.
Whitfield, C.L. A Gift to Myself: A Personal Guide to Healing My Child Within. Deerfield Beach, FL: Health Communications. 1990.
Whitfield, C.L. Boundaries and Relationships: Knowing, Protecting, and Enjoying the Self. Deerfield Beach, FL: Health Communications. 1993.
Whitfield, C.L. Memory and Abuse: Remembering and Healing the Effects of Trauma. Deerfield Beach, FL: Health Communications. 1995.
Whitfield, C.L. Internal corroboration of child sexual abuse. Journal of Child Sexual Abuse. 1997;6(3):99-122.
Whitfield, C.L. Traumatic amnesia: The evolution of our clinical and legal understanding. Sexual Addiction and Compulsivity. 1997;4(2):107-135.
Whitfield, C.L. Internal evidence and corroboration of traumatic memories of child sexual abuse and addictive disorders. Sexual Addiction and Compulsivity. 1998;5:269-292.
Widom, C.S.; Ireland, T.; and Glynn, P.J. Alcohol abuse in abused and neglected children followed-up: Are they at increased risk?. Journal of Studies on Alcohol. 1995;56:207-217.
Williams, L.M. Recall of childhood trauma: A prospective study of women's memories of child sexual abuse. Journal of Consulting and Clinical Psychology. 1994;62:1167-1176.
Wilson, J.P., and Lindy, J.D., eds. Countertransference in the Treatment of PTSD. New York: Guilford Press. 1994.
Windle, M.; Windle, R.C.; Scheidt, D.M.; and Miller, G.B. Physical and sexual abuse and associated mental disorders among alcoholic inpatients. . American Journal of Psychiatry. 1995;152(9):1322-1328. [pmid: 7653688].
Wolfe, D.A.; Sas, L.; and Wekerle, C. Factors associated with the development of posttraumatic stress disorder among child victims of sexual abuse. . Child Abuse and Neglect. 1994;18:37-50.
Wolfner, G.D., and Gelles, R.J. A profile of violence toward children: A national study. Child Abuse and Neglect. 1993;17:197-212.
Wolin, S., and Wolin, S. Resilience among youth growing up in substance-abusing families. Pediatric Clinics of North America. 1995;42(2):415-429. [pmid: 7724267].
Wyatt, G.E. The sexual abuse of Afro-American and White American women in childhood. Child Abuse and Neglect. 1985;9:507-519.
Wyatt, G.E., and Peters, S.D. Issues in the definition of child sexual abuse in prevalence research. Child Abuse and Neglect. 1986;10:231-240.
Wyatt, G.E., and Peters, S.D. Methodological considerations in research on the prevalence of child sexual abuse. Child Abuse and Neglect. 1986;10:241-251.
Young, E.B. The role of incest issues in relapse and recovery. In: Washton, A.M., ed. Psychotherapy and Substance Abuse: A Practitioner's Handbook. New York: Guilford Press. 1995.
Young, N.K.; Gardner, S.L.; and Dennis, K. Responding to Alcohol and Other Drug Problems in Child Welfare: Weaving Together Practice and Policy. Washington, DC: Child Welfare League of America. 1998.
Zierler, S.; Feingold, L.; Laufer, D.; Velentgas, P.; Kantrowitz-Gordon, I.; and Mayer, K. Adult survivors of childhood sexual abuse and subsequent risk of HIV infection. American Journal of Public Health. 1991;81(5):572-575. [pmid: 2014856].