# Appendix A -- Bibliography

Agency for Health Care Policy and Research. Smoking Cessation: Clinical Practice Guideline, Number 18. Washington, DC: U.S. Government Printing Office, 1996.
Alcoholics Anonymous. Alcoholics Anonymous: The Story of How Many Thousands of Men and Women Have Recovered From Alcoholism, 3rd ed. New York: Alcoholics Anonymous World Services, 1976.
Allen, J.P., and Columbus, M., eds. Assessing Alcohol Problems: A Guide for Clinicians and Researchers. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1995.
Allport, G.W.; Vernon, P.E.; and Lindzey, G. Study of Values: A Scale for Measuring the Dominant Interests in Personality, 3rd ed. Boston: Houghton-Mifflin, 1960.
Allsop, S.; Saunders, B.; Phillips, M.; and Carr, A. (1997). A trial of relapse prevention with severely dependent male problem drinkers. Addiction.
Alterman, A.I.; Kampman, K.; Boardman, C.R.; Cacciola, J.S.; Rutherford, M.J.; McKay, J.R.; and Maany, I. (1997). A cocaine-positive baseline urine predicts outpatient treatment attrition and failure to attain initial abstinence. Drug and Alcohol Dependence.
Alterman, A.I.; McKay, J.R.; Mulvaney, F.D.; and McLellan, A.T. (1996). Prediction of attrition from day hospital treatment in lower socioeconomic cocaine-dependent men. Drug and Alcohol Dependence.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. Washington, DC: American Psychiatric Association, 1994.
American Psychiatric Association. (1995). A Practice guideline for the treatment of substance use disorders: Alcohol, cocaine, opioids. American Journal of Psychiatry.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders, 2nd ed. Washington, DC: American Society of Addiction Medicine, 1996.
Anderson, P., and Scott, E. (1992). The effect of general practitioners' advice to heavy drinking men. British Journal of Addiction.
Anglin, M.D.; Hser, Y.; Crits-Cristoph, P.; Cummings, L.; Hall, S.; Kosten, T.R.; and Martin, W.R. Treatment research: 1989-1991. In: Drug Abuse and Drug Abuse Research: The Fourth Triennial Report to Congress From the Secretary, Department of Health and Human Services. Rockville, MD: National Institute on Drug Abuse, 1992 (unpublished).
Annis, H.M., and Davis, C.S. Self-efficacy and the prevention of alcoholic relapse: Initial findings from a treatment trial. In: Baker, T., and Cannon, D., eds. Assessment and Treatment of Addictive Disorders. New York: Praeger, 1988. pp. 88-112.
Annis, H.M., and Davis, C.S. (1991). Relapse prevention. Alcohol Health and Research World.
Annis, H.M., and Graham, J.M. Situational Confidence Questionnaire (SCQ-39): User's Guide. Toronto, ON: Addiction Research Foundation, 1988.
Annis, H.M., and Graham, J.M. Situational Confidence Questionnaire. Toronto, ON: Addiction Research Foundation, 1990.
Annis, H.M., and Graham, J.M. (1995). Profile types on the Inventory of Drinking Situations: Implications for relapse prevention counseling. Psychology of Addictive Behaviors.
Appelbaum, A. (1972). A critical re-examination of the concept of "motivation for change" in psychoanalytic treatment. International Journal of Psychoanalysis.
Aubrey, L.L. (1998). "Motivational interviewing with adolescents presenting for outpatient substance abuse treatment." Ph.D. diss., University of New Mexico. Dissertation Abstracts International.
Azrin, N.H., and Besalel, V.A. Job Club Counselor's Manual. A Behavioral Approach to Vocational Counseling. Baltimore, MD: University Park Press, 1980.
Azrin, N.H., and Besalel, V.A. Finding a Job. Berkeley, CA: Ten Speed Press, 1982.
Azrin, N.H.; Sisson, R.W.; Meyers, R.J.; and Godley, M.D. (1982). Alcoholism treatment by disulfiram and community reinforcement therapy. Journal of Behavior Therapy and Experimental Psychiatry.
Babor, T.F., and Grant, M., eds. Project on Identification and Management of Alcohol-Related Problems. Report on Phase II: A Randomized Clinical Trial of Brief Interventions in Primary Health Care. Geneva, Switzerland: World Health Organization, 1992.
Baer, J.S.; Marlatt, G.A.; Kivlahan, D.R.; Fromme, K.; Larimer, M.E.; and Williams, E. (1992). Experimental test of three methods of alcohol risk reduction with young adults. Journal of Consulting and Clinical Psychology.
Bandura, A. (1989). Human agency in social cognitive theory. American Psychologist.
Bandura, A. Self-Efficacy: The Exercise of Control. New York: W.H. Freeman, 1997.
Baumeister, R.F. The crystallization of discontent in the process of major life change. In: Heatherton, T.F., and Weinberger, J.L., eds. Can Personality Change? Washington, DC: American Psychological Association, 1994. pp. 281-294.
Beck, A.T.; Wright, F.D.; Newman, C.F.; and Liese, B.S. Cognitive Therapy of Substance Abuse. New York: Guilford Press, 1993.
Beckman, L.J. (1980). An attributional analysis of Alcoholics Anonymous. Journal of Studies on Alcohol.
Bernstein E.; Bernstein, J.; and Levenson, S. (1997). Project ASSERT: An ED-based intervention to increase access to primary care, preventive services, and the substance abuse treatment system. . Annals of Emergency Medicine.
Bernstein, E.; Bernstein, J.; Schulz, C.; and Shepard, D.S. Substance Abuse in New Hampshire: Intervention. Waltham, MA: Institute for Health Policy, Brandeis University, 1997b.
Bien, T.H. "Motivational intervention with alcohol outpatients." Ph.D. diss., University of New Mexico, 1992.
Bien, T.H.; Miller, W.R.; and Boroughs, J.M. (1993). Motivational interviewing with alcohol outpatients. Behavioral and Cognitive Psychotherapy.
Bien, T.H.; Miller, W.R.; and Tonigan, J.S. (1993). Brief interventions for alcohol problems: A review. Addiction.
Blomqvist, J. (1996). Paths to recovery from substance misuse: Change of lifestyle and the role of treatment. Substance Use and Misuse.
Borysenko, J., and Borysenko, M. The Power of the Mind to Heal: Renewing Body, Mind, and Spirit. Carson, CA: Hay House, 1995.
Brecht, M.L., and Anglin, M.D. (1990). Conditional factors of maturing out: Legal supervision and treatment. International Journal of the Addictions.
Brehm, S.S., and Brehm, J.W. Psychological Reactance: A Theory of Freedom and Control. New York: Academic Press, 1981.
Breslin, F.C.; Sobell, L.C.; Sobell, M.B.; and Buchan, G. "A comparison of a brief and long format for the Situational Confidence Questionnaire." Poster presented at the 31st Annual Meeting of the Association for Advancement of Behavior Therapy. Miami Beach, FL. November 1997.
Brown, J.M., and Miller, W.R. (1993). Impact of motivational interviewing on participation in residential alcoholism treatment. Psychology of Addictive Behaviors.
Brown, S.A. (1993). Drug effect expectancies and addictive behavior change. Experimental and Clinical Psychopharmacology.
Brown, S.A.; Christiansen, B.A.; and Goldman, M.S. (1987). The Alcohol Expectancy Questionnaire: An instrument for the assessment of adolescent and adult alcohol expectancies. Journal of Studies on Alcohol.
Brown, V.B.; Huba, G.J.; and Melchior, L.A. (1995). Level of burden: Women with more than one co-occurring disorder. Journal of Psychoactive Drugs.
Brown, V.B.; Melchior, L.A.; and Huba, G.J. (1999). Level of burden among women diagnosed with severe mental illness and substance abuse. Journal of Psychoactive Drugs.
Brown, V.B.; Melchior, L.A.; Panter, A.T.; Slaughter, R.; and Huba, G.J. Women's steps of change and entry into drug abuse treatment: A multidimensional stages of change model. Journal of Substance Abuse Treatment.
Brownell, K.D.; Marlatt, G.A.; Lichtenstein, E.; and Wilson, G.T. (1986). Understanding and preventing relapse. American Psychologist.
Budman, S., and Gurman, A. Theory and Practice of Brief Therapy. New York: Guilford Press, 1988.
Budney, A.J., and Higgins, S.T. Therapy Manuals for Drug Addiction. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. DHHS Pub. No. 98-4309, Washington, DC: U.S. Government Printing Office, 1998.
Carey, K.B. (1996). Substance use reduction in the context of outpatient psychiatric treatment: A collaborative, motivational, harm reduction approach. Community Mental Health Journal.
Carpenter, R.A.; Lyons, C.A.; and Miller, W.R. (1985). Peer-managed self-control program for prevention of alcohol abuse in American Indian high school students: A pilot evaluation study. . International Journal of the Addictions.
Carroll, M.E. (1993). The economic context of drug and non-drug reinforcers affects acquisition and maintenance of drug-reinforced behavior and withdrawal effects. Drug and Alcohol Dependence.
Center for Substance Abuse Treatment. Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 7. DHHS Pub. No. (SMA) 94-2076. Washington, DC: U.S. Government Printing Office, 1994a.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients with Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 9. DHHS Pub. No. (SMA) 94-2078. Washington, DC: U.S. Government Printing Office, 1994b.
Center for Substance Abuse Treatment. Assessment of Cocaine-Abusing Methadone-Maintained Patients. Treatment Improvement Protocol (TIP) Series, Number 10. DHHS Pub. No. (SMA) 94-3003, Washington, DC: U.S. Government Printing Office, 1994c.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Treatment Improvement Protocol (TIP) Series, Number 11. DHHS Pub. No. (SMA) 94-2094. Washington, DC: U.S. Government Printing Office, 1994d.
Center for Substance Abuse Treatment. Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 12. DHHS Pub. No. (SMA) 94-3004. Washington, DC: U.S. Government Printing Office, 1994e.
Center for Substance Abuse Treatment. The Role and Current Status of Patient Placement Criteria in the Treatment of Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 13. DHHS Pub. No. (SMA) 95-3021. Washington, DC: U.S. Government Printing Office, 1995a.
Center for Substance Abuse Treatment. Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 17. DHHS Pub. No. (SMA) 95-3039. Washington, DC: U.S. Government Printing Office, 1995b.
Center for Substance Abuse Treatment. Matching Treatment to Patient Needs in Opioid Substitution Therapy. Treatment Improvement Protocol (TIP) Series, Number 20. DHHS Pub. No. (SMA) 95-3049. Washington, DC: U.S. Government Printing Office, 1995c.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series, Number 24. DHHS Pub. No. (SMA) 97-3139. Washington, DC: U.S. Government Printing Office, 1997.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series, Number 29. DHHS Pub. No. (SMA) 98-3249. Washington, DC: U.S. Government Printing Office, 1998a.
Center for Substance Abuse Treatment. Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series, Number 30. DHHS Pub. No. (SMA) 98-3245. Washington, DC: U.S. Government Printing Office, 1998b.
Center for Substance Abuse Treatment. Brief Interventions and Brief Therapies for Substance Abuse. Treatment Improvement Protocol (TIP) Series. DHHS Pub. No. (SMA) 99-3353. Washington, DC: U.S. Government Printing Office, in press (a).
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series. Washington, DC: U.S. Government Printing Office, in press (b).
Chafetz, M.E.; Blane, H.T.; Abram, H.S.; Clark, E.; Golner, J.; Hastie, E.L.; and McCourt, W.F. (1964). Establishing treatment relations with alcoholics: A supplementary report. Journal of Nervous and Mental Disease.
Chafetz, M.E.; Blane, H.T.; Abram, H.S.; Golner, J.; Lacy, E.; McCourt, W.F.; Clark, E.; and Meyers, W. (1962). Establishing treatment relations with alcoholics. Journal of Nervous and Mental Disease.
Chamberlain, P.; Patterson, G.; Reid, J.; Kavanaugh, K.; and Forgatch, M. (1984). Observation of client resistance. Behavior Therapy.
Chapman, P.L.H., and Huygens, I. (1988). An evaluation of three treatment programmes for alcoholism: An experimental study with 6- and 18-month follow-up. British Journal of Addiction.
Chen, K., and Kandel, D.B. (1995). The natural history of drug use from adolescence to mid-thirties in a general population sample. American Journal of Public Health.
Chick, J.; Lloyd, G.; and Crombie, E. (1985). Counselling problem drinkers in medical wards: A controlled study. British Medical Journal.
Chick, J.; Ritson, B.; Connaughton, J.; Stewart, A; and Chick, J. (1988). Advice versus extended treatment for alcoholism: A controlled study. British Journal of Addiction.
Christiansen, B.A.; Goldman, M.S.; and Inn, A. (1982). Development of alcohol-related expectancies in adolescents: Separating pharmacological from social learning influences. Journal of Consulting and Clinical Psychology.
Colby, S.M.; Monti, P.M.; Barnett, N.P.; Rohsenow, D.J.; Weissman, K.; Spirito, A.; Woolard, R.H.; and Lewander, W.J. (1998). Brief motivational interviewing in a hospital setting for adolescent smoking: A preliminary study. Journal of Consulting and Clinical Psychology.
Collins, R.L.; Lapp, W.M.; Emmons, K.M.; and Isaac, L.M. (1990). Endorsement and strength of alcohol expectancies. Journal of Studies on Alcohol.
Colten, M.E., and Janis, I.L. Effects of moderate self-disclosure and the balance sheet procedure. In: Janis, I.L., ed. Counseling on Personal Decisions: Theory and Research on Short-Term Help Relationships. New Haven, CT: Yale University Press, 1982. pp. 159-171.
Connors, G.J., and Maisto, S.A. (1988). Alcohol expectancy construct: Overview and clinical applications. Cognitive Therapy and Research.
Connors, G.J.; O'Farrell, T.J.; Cutter, H.S.G.; and Thompson, D.L. (1987). Dose-related effects of alcohol among male alcoholics, problem drinkers, and nonproblem drinkers. Journal of Studies on Alcohol.
Costello, R.M. (1975). Alcoholism treatment and evaluation: In search of methods. II. Collation of two-year follow-up studies. International Journal of the Addictions.
Cota, A.A.; Longman, R.S.; Evans, C.R.; Dion, K.L.; and Kilik, L. (1995). Using and misusing factor analysis to explore group cohesion. Journal of Clinical Psychology.
Cox, W.M.; Klinger, E.; and Blount, J.P. Alcohol use and goal hierarchies: Systematic motivational counseling for alcoholics. In: Miller, W.R., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behaviors. New York: Guilford Press, 1993. pp. 260-271.
Cummings, C.; Gordon, J.R.; and Marlatt, G.A. Relapse: Prevention and prediction. In: Miller, W.R., ed. The Addictive Behaviors: Treatment of Alcoholism, Drug Abuse, Smoking, and Obesity. Oxford: Pergamon Press, 1980. pp. 291-321.
Cunningham, J.A.; Sobell, L.C.; Gavin, D.R.; Sobell, M.B.; and Breslin, F.C. (1997). Assessing motivation for change: Preliminary development and evaluation of a scale measuring the costs and benefits of alcohol or drug use. Psychology of Addictive Behaviors.
Cunningham, J.A.; Sobell, M.B.; Sobell, L.C.; Gavin, D.R.; and Annis, H.M. (1995). Heavy drinking and negative affective situations in a general population and a treatment sample: Alternative explanations. Psychology of Addictive Behaviors.
Daley, D.C.; Salloum, I.M.; Zuckoff, A.; Kiricsi, L.; and Thase, M.E. (1998). Increasing treatment adherence among outpatients with depression and cocaine dependence: Results of a pilot study. American Journal of Psychiatry.
Daniels, V.; Somers, M.; and Orford, J. (1992). How can risk drinking amongst medical patients be modified? The effects of computer screening and advice and a self-help manual. Behavioral Psychotherapy.
Davidson, R. (1994). Can psychology make sense of change? In: Edwards, G., and Lader, M., eds. Addiction: Processes of Change. Society for the Study of Addiction Monograph No. 3. New York: Oxford University Press.
Deci, E.L. Intrinsic Motivation. New York: Plenum Press, 1975.
Deci, E.L. The Psychology of Self-Determination. Lexington, MA: Lexington Books, 1980.
De Leon, G.; Melnick, G.; Kressel, D.; and Jainchill, N. (1994). Circumstances, motivation, readiness, and suitability (the CMRS Scales): Predicting retention in therapeutic community treatment. American Journal of Drug and Alcohol Abuse.
DiClemente, C.C. Motivational interviewing and the stages of change. In: Miller, W.R., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991. pp. 191-202.
DiClemente, C.C.; Carbonari, J.P.; Montgomery, R.P.G.; and Hughes, S.O. (1994). The Alcohol Abstinence Self-Efficacy Scale. Journal of Studies on Alcohol.
DiClemente, C.C., and Prochaska, J.O. Processes and stages of self-change: Coping and competence in smoking behavior change. In: Shiffman, S., and Wills, T.A., eds. Coping and Substance Abuse. New York: Academic Press, 1985. pp. 319-343.
DiClemente, C.C., and Prochaska, J.O. Toward a comprehensive transtheoretical model of change: Stages of change and addictive behaviors. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors, 2nd ed. New York: Plenum Press, 1998.
DiClemente, C.C., and Scott, C.W. Stages of change: Interactions with treatment compliance and involvement. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug-Dependent Individual in Treatment. NIDA Research Monograph Series, Number 165. DHHS Pub. No. (ADM) 97-4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 131-156.
Dies, R.R., ed. The Therapist's Role in Group Treatments. New York: Guilford Press, 1994.
D'Onofrio, G.; Bernstein, E.; Bernstein, J.; Woolard, R.H.; Brewer, P.A.; Craig, S.A.; and Zink, B.J. (1998). Patients with alcohol problems in the emergency department, Part 2: Intervention and referral. Academic Emergency Medicine.
Drummond, D.C. (1997). Alcohol interventions: Do the best things come in small packages?. Addiction.
Drummond, D.C.; Thom, B.; Brown, C.; Edwards, G.; and Mullan, M.J. (1990). Specialist versus general practitioner treatment of problem drinkers. Lancet.
Eastwood, G.L., and Avunduk, C. Manual of Gastroenterology: Diagnosis and Therapy, 2nd ed. New York: Little, Brown and Company, 1994.
Edwards, G.; Orford, J.; Egert, S.; Guthrie, S.; Hawken, A.; Hensman, C.; Mitcheson, M.; Oppenheimer, E.; and Taylor, C. (1977). Alcoholism: A controlled trial of "treatment" and "advice.". Journal of Studies on Alcohol.
Ellis, A., and Velten, E. When AA Doesn't Work for You: Rational Steps to Quitting Alcohol. Fort Lee, NJ: Barricade Books, 1992.
Elvy, G.A.; Wells, J.E.; and Baird, K.A. (1988). Attempted referral as intervention for problem drinking in the general hospital. British Journal of Addiction.
Fleming, M.F.; Barry, K.L.; Manwell, L.B.; Johnson, K.; and London, R. (1997). Brief physician advice for problem alcohol drinkers: A randomized controlled trial in community-based primary care practices. . JAMA.
Fosnocht, K.M. (1998). Cost-effectiveness of the AHCPR guidelines for smoking. JAMA.
Galanter, M.; Keller, D.S.; and Dermatis, H. (1997). Network Therapy for addiction: Assessment of the clinical outcome of training. American Journal of Drug and Alcohol Abuse.
Gavin, D.R.; Sobell, L.C.; and Sobell, M.B. (1998). Evaluation of the Readiness to Change Questionnaire with problem drinkers in treatment. Journal of Substance Abuse.
Goddard, L., ed. An African Centered Model of Prevention for African-American Youth at High Risk. Washington, DC: U.S. Government Printing Office, 1992.
Gordon, T. Parent Effectiveness Training: The No-Lose Program for Raising Responsible Children. New York: Wyden, 1970.
Grills, C., and Rowe, D. African traditional medicine: Implications for African centered approaches to healing. In: Jones, R., ed. African American Mental Health. Hampton, VA: Cobb and Henry, 1998.
Handmaker, N.S.; Miller, W.R.; and Manicke, M. (1999). Findings of a pilot study of motivational interviewing with pregnant drinkers. Journal of Studies on Alcohol.
Harris, K.B., and Miller, W.R. (1990). Behavioral self-control training for problem drinkers: Components of efficacy. Psychology of Addictive Behaviors.
Heather, N. (1995). Interpreting the evidence on brief interventions for excessive drinkers: The need for caution. Alcohol and Alcoholism.
Heather, N.; Kissoon-Singh, J.; and Fenton, G.W. (1990). Assisted natural recovery from alcohol problems: Effects of a self-help manual with and without supplementary telephone contact. British Journal of Addiction.
Heather, N.; Luce, A.; Peck, D.; and Dunbar, B. (1996a). "Development of the Readiness to Change Questionnaire (Treatment Version)." Report to the Northern and Yorkshire R & D Directorate.
Heather N.; Robertson, I.; MacPherson, B.; Allsop, S.; and Fulton, A. (1987). Effectiveness of a controlled drinking self-help manual: One year follow-up results. British Journal of Clinical Psychology.
Heather, N.; Rollnick, S.; and Bell, A. (1993). Predictive validity of the Readiness to Change Questionnaire. Addiction.
Heather, N.; Rollnick, S.; Bell, A.; and Richmond, R. (1996). Effects of brief counseling among male heavy drinkers identified on general hospital wards. Drug and Alcohol Review.
Heather, N.; Whitton, B.; and Robertson, I. (1986). Evaluation of a self-help manual for media-recruited problem drinkers: Six month follow-up results. British Journal of Clinical Psychology.
Helzer, J.E., and Pryzbeck, T.R. (1988). Co-occurrence of alcoholism with other psychiatric disorders in the general population and its impact on treatment. Journal of Studies on Alcohol.
Higgins, S.T.; Bickel, W.K.; and Hughes, J.R. (1994). Influence of an alternative reinforcer on human cocaine self-administration. Life Sciences.
Higgins, S.T., and Budney, A.J. (1993). Treatment of cocaine dependence through the principles of behavior analysis and behavioral pharmacology. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Behavioral Treatments for Drug Abuse and Dependence. Rockville, MD: National Institute on Drug Abuse.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Badger, G.J.; Foerg, F.E.; and Ogden, D. (1995). Outpatient behavioral treatment for cocaine dependence: One-year outcome. Experimental and Clinical Psychopharmacology.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Foerg, F.; Donham, R.; and Badger, M.S. (1994). Incentives improve outcome in outpatient behavioral treatment of cocaine dependence. Archives of General Psychiatry.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Badger, G. (1993). Achieving cocaine abstinence with a behavioral approach. American Journal of Psychiatry.
Higgins, S.T., and Silverman, K. Motivating Behavior Change Among Illicit Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999.
Holder, H.; Longabaugh, R.; Miller, W.R.; and Rubonis, A.V. (1991). The cost effectiveness of treatment for alcoholism: A first approximation. Journal of Studies on Alcohol.
Hunt, G.M., and Azrin, N.H. (1973). A community-reinforcement approach to alcoholism. Behavioral Research and Therapy.
Hurt, R.D.; Offord, K.P.; Croghan, I.T.; Gomez-Dahl, L.; Kottke, T.E.; Morse, R.M.; and Melton, J. (1996). Mortality following inpatient addictions treatment: Role of tobacco use in a community-based cohort. JAMA.
Inciardi, J.A; Tims, F.M.; and Fletcher, B. Innovative Approaches to the Treatment of Drug Abuse: Program Models and Strategies. Westport, CT: Greenwood, 1993.
Ingersoll, K.S., and Wagner, C.C. Motivational Enhancement Groups for the Virginia Substance Abuse Treatment Outcomes Evaluation (SATOE) Model: Theoretical Background and Clinical Guidelines. Richmond, VA: Office of Mental Health Services, Department of Mental Health, Mental Retardation and Substance Abuse Services, 1997.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Report of a Study by a Committee of the Institute of Medicine, Division of Mental Health and Behavioral Medicine. Washington, DC: National Academy Press, 1990a.
Institute of Medicine. Treating Drug Problems. Washington, DC: National Academy Press, 1990b.
Intagliata, J. (1976). A telephone follow-up procedure for increasing the effectiveness of a treatment program for alcoholics. Journal of Studies on Alcohol.
Ivey, A.E.; Gluckstern, N.B.; and Ivey, M.B. Basic Influencing Skills. 3rd ed. North Amherst, MA: Microtraining Associates, 1997.
Jaffee, J.H. The swinging pendulum: The treatment of drug users in America. In: Dupont, R.L.; Goldstein, A.; O'Donnell, J.; and Brown, B., eds. Handbook on Drug Abuse. Rockville, MD: National Institute on Drug Abuse, 1979. pp. 3-16.
Janis, I.L., and Mann, L. Decision Making: A Psychological Analysis of Conflict, Choice, and Commitment. London: Cassel and Collier Macmillan, 1977.
Johnson, V.E. I'll Quit Tomorrow. New York: Harper & Row, 1973.
Jones, R.A. Self-Fulfilling Prophecies: Social, Psychological, and Physiological Effects of Expectancies. Hillsdale, NJ: L. Erlbaum, 1977.
Kahan, M.; Wilson, L.; and Becker, L. (1995). Effectiveness of physician-based interventions with problem drinkers: A review. Canadian Medical Association Journal.
Kanfer, F.H. Self-regulation: Research, issues, and speculations. In: Neuringer, C., and Michael, J.L., eds. Behavior Modification in Clinical Psychology. New York: Appleton-Century-Crofts, 1970. pp. 178-220.
Kanfer, F.H., and Schefft, B.K. Guiding the Process of Therapeutic Change. Champaign, IL: Research Press, 1988.
Keller, D.S.; Galanter, M.; and Weinberg, S. (1997). Validation of a scale for network therapy: A technique for systematic use of peer and family support in addiction treatment. American Journal of Drug and Alcohol Abuse.
Kent, R. Motivational interviewing and the maintenance of change. In: Miller, W.R., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991. pp. 191-202.
Khantzian, E.J. An ego/self theory of substance dependence: A contemporary psychoanalytic perspective. In: Lettieri, D.J.; Sayers, M.; and Pearson, H.W., eds. Theories on Drug Abuse: Selected Contemporary Perspectives. NIDA Research Monograph Series, Number 30. DHHS Publication No. (ADM) 80-967. Washington, DC: U.S. Government Printing Office, 1980. pp. 29-33.
Khantzian, E.J.; Halliday, K.S.; and McAuliffe, W.E. Addiction and the Vulnerable Self: Modified Dynamic Group Therapy for Substance Abusers. New York: Guilford Press, 1990.
Kilpatrick, D.G.; Roitzsch, J.C.; Best, C.L.; McAlhany, D.A.; Sturgis, E.T.; and Miller, W.C. (1978). Treatment goal preference and problem perception of chronic alcoholics: Behavioral and personality correlates. Addictive Behaviors.
Klingemann, H.K. (1991). The motivation for change from problem alcohol and heroin use. British Journal of Addiction.
Kolden, G.G.; Howard, K.I.; Bankoff, E.A.; Maling, M.S.; and Martinovich, Z. Factors associated with treatment continuation: Implications for the treatment of drug dependence. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug-Dependent Individual in Treatment. NIDA Research Monograph Series, Number 165. DHHS Pub. No. (ADM) 97-4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 110-130.
Kopel, S., and Arkowitz, H. (1975). The role of attribution and self-perception in behavior change: Implications for behavior therapy. Genetic Psychology Monographs.
Koumans, A.J.R., and Muller, J.J. (1965). Use of letters to increase motivation in alcoholics. Psychology Reports.
Kris, A.O. (1984). The conflict of ambivalence. Psychoanalytical Study of the Child 39:213-234.
Kristenson, H.; Ohlin, H.; Hulten-Nosslin, M.B.; Trell, E.; and Hood, B. (1983). Identification and intervention of heavy drinking in middle-aged men: Results and follow-up of 24-60 months of long-term study with randomized controls. Alcoholism: Clinical and Experimental Research.
Kuchipudi, V.; Hobein, K.; Flickinger, A.; and Iber, F.L. (1990). Failure of a 2-hour motivational intervention to alter recurrent drinking behavior in alcoholics with gastrointestinal disease. Journal of Studies on Alcohol.
Landry, M.J. Overview of Addiction Treatment Effectiveness. DHHS Pub. No. (SMA) 96-3081. Rockville, MD: Substance Abuse and Mental Health Services Administration, Office of Applied Studies, 1996.
Landry, M.J.; Smith, D.E.; and Steinberg, J.R. (1991). Anxiety, depression, and substance use disorders: Diagnosis, treatment, and prescribing practices. Journal of Psychoactive Drugs.
Leake, G.J., and King, S.A. (1977). Effect of counselor expectations on alcoholic recovery. Alcohol Health and Research World.
Leigh, B.C. (1989). Confirmatory factor analysis of alcohol expectancy scales. Journal of Studies on Alcohol.
Leigh, B.C. (1989). In search of the seven dwarves: Issues of measurement and meaning in alcohol expectancy research. Psychological Bulletin.
Leukefeld, C.G., and Tims, F.M. Compulsory treatment: A review of findings. In: Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. NIDA Research Monograph Series, Number 86. DHHS Pub. No. (ADM) 88-1578. Rockville, MD: National Institute on Drug Abuse, 1988. pp. 236-251.
Leventhal, H. (1971). Fear appeals and persuasion: The differentiation of a motivational construct. American Journal of Public Health.
Liepman, M.R.; Nirenberg, T.D.; and Begin, A.M. (1989). Evaluation of a program designed to help family and significant others to motivate resistant alcoholics into recovery. American Journal of Drug and Alcohol Abuse.
Loberg, T., and Miller, W.R. (1986). Personality, cognitive, and neuropsychological correlates of harmful alcohol consumption: A cross-national comparison of clinical samples. Annals of the New York Academy of Sciences.
Loneck, B.; Garrett, J.A.; and Banks, S.M. (1996). A comparison of the Johnson intervention with four other methods of referral to outpatient treatment. American Journal of Drug and Alcohol Abuse.
Loneck, B.; Garrett, J.A.; and Banks, S.M. (1996). The Johnson intervention and relapse during outpatient treatment. American Journal of Drug and Alcohol Abuse.
Longabaugh, R.; Beattie, M.; Noel, N.; Stout, R.; and Malloy, P. (1993). The effect of social investment on treatment outcome. Journal of Studies on Alcohol.
Longshore, D., and Grills, C. (1998). Drug problem recognition among African American drug-using arrestees. Addictive Behaviors.
Longshore, D.; Grills, C.; Anglin, D.; and Annon, K. (1998). Treatment motivation among African-American drug using arrestees. Journal of Black Psychology.
Luborsky, L.; McLellan, A.T.; Woody, G.E.; O'Brien, C.P.; and Auerbach, A. (1985). Therapist success and its determinants. Archives of General Psychiatry.
Luke, D. (1998). "Teens' images of smoking and smokers." Paper presented at the annual meeting of the Society for Research on Nicotine and Tobacco, New Orleans, LA.
MacKenzie, K.R., ed. The Clinical Application of a Group Climate Measure. New York: International Universities Press, 1983.
Marlatt, G.A.; Baer, J.S.; Kivlahan, D.R.; Dimeff, L.A., Larimer, M.E., Quigley, L.A.; Somers, J.M.; and Williams, E. (1998). Screening and brief intervention for high-risk college student drinkers: Results from a 2-year follow-up assessment. Journal of Consulting and Clinical Psychology.
Marlatt, G.A., and George, W.H. (1984). Relapse prevention: Introduction and overview of the model. British Journal of Addiction.
Marlatt, G.A., and Gordon, J.R., eds. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors. New York: Guilford Press, 1985.
Marlatt, G.A., and Kristeller, J. Mindfulness and meditation. In: Miller, W.R., ed. Integrating Spirituality Into Treatment: Resources for Practitioners. Washington, DC: American Psychological Association, 1999.
Mattick, R.P., and Jarvis, T. (1994). Brief or minimal intervention for 'alcoholics'? The evidence suggests otherwise. Drug and Alcohol Review.
McAuliffe, W.E., and Gordon, R.A. Reinforcement and the combination of effects: Summary of a theory of opiate addiction. In: Lettieri, D.J.; Sayers, M.; and Wallenstein-Pearson, H., eds. Theories on Drug Abuse: Selected Contemporary Perspectives. NIDA Research Monograph Series, Number 30. DHHS Pub. No. (ADM) 80-967. Washington, DC: U.S. Government Printing Office, 1980. pp. 137-141.
McCaul, M.E., and Svikis, D.S. Improving client compliance in outpatient treatment: Counselor-targeted interventions. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R. Improving Drug Abuse Treatment. NIDA Research Monograph Series, Number 106. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 204-217.
McConnaughy, E.A.; Prochaska, J.O.; and Velicer, W.F. Stages of change in psychotherapy: Measurement and sample profiles. Psychotherapy: Theory, Research and Practice 20:368-375, 1983.
McLellan, A.T.; Alterman, A.I.; Metzger, D.S.; Grisson, G.R.; Woody, G.E.; Luborsky, L.; and O'Brien, C.P. (1994). Similarity of outcome predictors across opiate, cocaine, and alcohol treatments: Role of treatment services. Journal of Consulting and Clinical Psychology.
Melchior, L.A.; Huba, G.J.; Brown, V.B.; and Slaughter, R. Evaluation of the effects of outreach to women with multiple vulnerabilities on entry into substance abuse treatment. Evaluation and Program Planning, in press.
Meyers, R.J., and Smith, J.E. Clinical Guide to Alcohol Treatment: The Community Reinforcement Approach. New York: Guilford Press, 1995.
Meyers, R.J., and Smith, J.E. (1997). Getting off the fence: Procedures to engage treatment-resistant drinkers. Journal of Substance Abuse Treatment.
Miller, L. (1985). Neuropsychological assessment of substance abusers: Review and recommendations. Journal of Substance Abuse Treatment.
Miller, W.R. (1976). Alcoholism scales and objective assessment methods: A review. Psychological Bulletin.
Miller, W.R. (1983). Motivational interviewing with problem drinkers. Behavioural Psychotherapy.
Miller, W.R. (1985). Motivation for treatment: A review with special emphasis on alcoholism. Psychological Bulletin.
Miller, W.R. Increasing motivation for change. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives, 2nd ed. Boston: Allyn & Bacon, 1995. pp. 89-104.
Miller, W.R. (1996). What is a relapse? Fifty ways to leave the wagon. Addiction.
Miller, W.R.; Andrews, N.R.; Wilbourne, P.; and Bennett, M.E. A wealth of alternatives: Effective treatments for alcohol problems. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors: Processes of Change, 2nd ed. New York: Plenum Press, 1998. pp. 203-216.
Miller, W.R., and Baca, L.M. (1983). Two-year follow-up of bibliotherapy and therapist-directed controlled drinking training for problem drinkers. Behavior Therapy.
Miller, W.R.; Benefield, R.G.; and Tonigan, J.S. (1993). Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting and Clinical Psychology.
Miller, W.R.; Brown, J.M.; Simpson, T.L.; Handmaker, N.S.; Bien, T.H.; Luckie, L.F.; Montgomery, H.A.; Hester, R.K.; and Tonigan, J.S. What works? A methodological analysis of the alcohol treatment outcome literature. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives, 2nd ed. Boston: Allyn & Bacon, 1995a. pp. 12-44.
Miller, W.R., and C'de Baca, J. Quantum change: Toward a psychology of transformation. In: Heatherton, T., and Weinberger, J., eds. Can Personality Change? Washington, DC: American Psychological Association, 1994. pp. 253-280.
Miller, W.R.; Gribskov, C.J.; and Mortell, R.L. (1981). Effectiveness of a self-control manual for problem drinkers with and without therapist contact. International Journal of the Addictions.
Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors, 2nd ed. New York: Plenum Press, 1998.
Miller, W.R., and Kurtz, E. (1994). Models of alcoholism used in treatment: Contrasting AA and other perspectives with which it is often confused. Journal of Studies on Alcohol.
Miller, W.R.; Leckman, A.L; Delaney, H.D.; and Tinkcom, M. (1992). Long-term follow-up of behavioral self-control training. Journal of Studies on Alcohol.
Miller, W.R., and Meyers, R.J. Engaging unmotivated individuals in treatment for alcohol problems: A comparison of three intervention strategies. Journal of Consulting and Clinical Psychology.
Miller, W.R., and Page, A.C. (1991). Warm turkey: Other routes to abstinence. . Journal of Substance Abuse Treatment.
Miller, W.R., and Pechacek, T.F. (1987). New roads: Assessing and treating psychological dependence. Journal of Substance Abuse Treatment.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991.
Miller, W.R., and Sanchez, V.C. Motivating young adults for treatment and lifestyle change. In: Howard, G., and Nathan, P.E., eds. Alcohol Use and Misuse by Young Adults. Notre Dame, IN: University of Notre Dame Press, 1994.
Miller, W.R., and Saucedo, C.F. Assessment of neuropsychological impairment and brain damage in problem drinkers. In: Golden, C.J.; Moses, J.A., Jr.; Coffman, J.A.; Miller, W.R.; and Strider, F.D., eds. Clinical Neuropsychology: Interface With Neurologic and Psychiatric Disorders. New York: Grune & Stratton, 1983. pp. 141-195.
Miller, W.R., and Sovereign, R.G. The check-up: A model for early intervention in addictive behaviors. In: Loberg, T.; Miller, W.R.; Nathan, P.E.; and Marlatt, G.A., eds. Addictive Behaviors: Prevention and Early Intervention. Amsterdam: Swets & Zeitlinger, 1989. pp. 219-231.
Miller, W.R.; Sovereign, R.G.; and Krege, B. (1988). Motivational interviewing with problem drinkers: II. The Drinker's Check-up as a preventive intervention. Behavioural Psychotherapy.
Miller, W.R., and Taylor, C.A. (1980). Relative effectiveness of bibliotherapy, individual and group self-control training in the treatment of problem drinkers. Addictive Behaviors.
Miller, W.R.; Taylor, C.A.; and West, J.C. (1980). Focused versus broad-spectrum behavior therapy for problem drinkers. Journal of Consulting and Clinical Psychology.
Miller, W.R., and Tonigan, J.S. (1996). Assessing drinkers' motivation for change: The Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES). Psychology of Addictive Behaviors.
Miller, W.R.; Westerberg, V.S.; and Waldron, H.B. Evaluating alcohol problems. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives, 2nd ed. Boston: Allyn & Bacon, 1995b. pp. 61-88.
Miller, W.R.; Zweben, A.; DiClemente, C.C.; and Rychtarik, R.G. Motivational Enhancement Therapy Manual: A Clinical Research Guide for Therapists Treating Individuals With Alcohol Abuse and Dependence. Project MATCH Monograph Series, Vol. 2. NIH Pub. No. 94-3723. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism, 1995c.
Moos, R.H.; Brennan, P.L.; Fondacaro, M.R.; and Moos, B.S. (1990). Approach and avoidance coping responses among older problem and nonproblem drinkers. Psychology and Aging.
Najavits, L.M., and Weiss, R.D. (1994). Variations in therapist effectiveness in the treatment of patients with substance use disorders: An empirical review. Addiction.
Nir, Y., and Cutler, R. (1978). The unmotivated patient syndrome: Survey of therapeutic interventions. American Journal of Psychiatry.
Nirenberg, T.D.; Sobell, L.C.; and Sobell, M.B. (1980). Effective and inexpensive procedures for decreasing client attrition in an outpatient alcohol treatment program. American Journal of Drug and Alcohol Abuse.
Noonan, W.C., and Moyers, T.B. (1997). Motivational interviewing. Journal of Substance Misuse.
Obert, J.L.; Rawson, R.A.; and Miotto, K. (1997). Substance abuse treatment for "hazardous users": An early intervention. Journal of Psychoactive Drugs.
Ockene, J.K.; Wheeler, E.V.; Adams, A.; Hurley, T.G.; and Hebert, J. (1997). Provider training for patient-centered alcohol counseling in a primary care setting. Archives of Internal Medicine.
O'Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993.
Orford, J. Excessive Appetites: A Psychological View of Addictions. New York: John Wiley and Sons, 1985.
Orford, J. (1994). Empowering family and friends: A new approach to the secondary prevention of addiction. Drug and Alcohol Review.
Orleans, C.T.; Schoenbach, V.J.; Wagner, E.H.; Quade, D.; Salmon, M.A.; Pearson, D.C.; Fiedler, J.; Porter, C.Q.; and Kaplan, B.H. (1991). Self-help quit smoking interventions: Effects of self-help materials, social support instructions, and telephone counseling. Journal of Consulting and Clinical Psychology.
Panepinto, W.C., and Higgins, M.J. (1969). Keeping alcoholics in treatment: Effective follow-through procedures. Quarterly Journal of Studies on Alcohol.
Parker, M.W.; Winstead, D.K.; and Willi, F.J. (1979). Patient autonomy in alcohol rehabilitation: I. Literature review. International Journal of the Addictions.
Pattison, E.M.; Sobell, M.B.; and Sobell, L.C. Emerging Concepts of Alcohol Dependence. New York: Springer, 1977.
Persson, J., and Magnusson, P.H. (1989). Early intervention in patients with excessive consumption of alcohol: A controlled study. Alcohol: An International Biomedical Journal.
Perz, C.A.; DiClemente, C.C.; and Carbonari, J.P. (1996). Doing the right thing at the right time? The interaction of stages and processes of change in successful smoking cessation. Health Psychology.
Peterson, L.; Gable, S.; and Saldana, L. (1996). Treatment of maternal addiction to prevent child abuse and neglect. Addictive Behaviors.
Pickens, R.W., and Fletcher, B.W. Overview of treatment issues. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Abuse Treatment. NIDA Research Monograph Series, Number 106. DHHS Pub. No. (ADM) 91-1754. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 1-19.
Polich, J.M.; Armor, D.J.; and Braiker, H.B. The Course of Alcoholism: Four Years After Treatment. New York: John Wiley and Sons, 1981.
Prochaska, J.O. Systems of Psychotherapy: A Transtheoretical Analysis. Homewood, IL: Dorsey Press, 1979.
Prochaska, J.O., and DiClemente, C.C. (1983). Stages and processes of self-change of smoking: Toward an integrated model of change. Journal of Consulting and Clinical Psychology.
Prochaska, J.O., and DiClemente, C.C. The Transtheoretical Approach: Crossing Traditional Boundaries of Therapy. Homewood, IL: Dow Jones-Irwin, 1984.
Prochaska, J.O., and DiClemente, C.C. Stages of change in the modification of problem behaviors. In: Hersen, M.; Eisler, R.M.; and Miller, P.M., eds. Progress in Behavior Modification. Sycamore, IL: Sycamore Publishing Company, 1992. pp. 184-214.
Prochaska, J.O; DiClemente, C.C.; and Norcross, J.C. Changing: Process approaches to initiation and maintenance of changes. In: Klar, Y.; Fisher, J.D.; Chinsky, J.M.; and Nadler, A., eds. Self-Change: Social, Psychological, and Clinical Perspectives. New York: Springer-Verlag, 1992a. pp. 87-114.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. (1992). In search of how people change: Applications to addictive behaviors. American Psychologist.
Prochaska, J.O., and Goldstein, M.G. (1991). Process of smoking cessation: Implications for clinicians. Clinical Chest Medicine.
Prochaska, J.O.; Velicer, W.F.; Rossi, J.S.; Goldstein, M.G.; Marcus, B.H.; Rakowski, W.; Fiore, C.; Harlow, L.L.; Redding, C.A., Rosenbloom, D.; and Rossi, S.R. (1994). Stages of change and decisional balance for 12 problem behaviors. Health Psychology.
Project MATCH Research Group. (1997). Matching alcoholism treatments to client heterogeneity: Project MATCH posttreatment drinking outcomes. Journal of Studies on Alcohol.
Project MATCH Research Group. (1998). Matching alcoholism treatments to client heterogeneity: Project MATCH three-year drinking outcomes. Alcoholism: Clinical and Experimental Research.
Project MATCH Research Group. (1997). Project MATCH secondary a priori hypotheses. Addiction.
Project MATCH Research Group. (1998). Therapist effects in three treatments for alcohol problems. . Psychotherapy Research.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; Smith, D.P.; and Scheffey, E.H. The Neurobehavioral Treatment Manual. Beverly Hills, CA: Matrix, 1989.
Rawson, R.A.; Shoptaw, S.J.; Obert, J.L.; McCann, M.J.; Hasson, A.L.; Marinelli-Casey, P.J.; Brethen, P.R.; and Ling, W. (1995). An intensive outpatient approach for cocaine abuse treatment: The Matrix model. Journal of Substance Abuse Treatment.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.J.; Judd, L.L.; and Goodwin, F.K. (1990). Comorbidity of mental disorders with alcohol and other drug abuse. JAMA.
Richmond, R.L.; Kehoe, L.A.; and Webster, I.W. (1993). Multivariate models for predicting abstention following interventions to stop smoking by general practitioners. Addiction.
Robertson, I.; Heather, N.; Dzialdowski, A.; Crawford, J.; and Winton, M. (1986). Comparison of minimal versus intensive controlled drinking treatment interventions for problem drinkers. British Journal of Clinical Psychology.
Robins, L.N.; Davis, D.H.; and Goodwin, D.W. (1974). Drug use by U.S. Army enlisted men in Vietnam: A follow-up on their return home. American Journal of Epidemiology.
Rogers, C.R. A theory of therapy, personality, and interpersonal relationships as developed in the client-centered framework. In: Koch, S., ed. Psychology: A Study of a Science. Vol. 3, Formulations of the Person and the Social Context. New York: McGraw-Hill, 1959. pp. 184-256.
Rogers, R.W.; Deckner, C.W.; and Mewborn, C.R. (1978). An expectancy-value theory approach to the long-term modification of smoking behavior. Journal of Clinical Psychology.
Rokeach, M. The Nature of Human Values. New York: Free Press, 1973.
Rokeach, M. Rokeach Value Survey. Palo Alto, CA: Consulting Psychologists Press, 1983.
Rollnick, S.; Heather, N.; and Bell, A. (1992). Negotiating behavior change in medical settings: The development of brief motivational interviewing. Journal of Mental Health.
Rollnick, S.; Heather, N.; Gold, R.; and Hall, W. (1992). Development of a short "readiness to change" questionnaire for use in brief, opportunistic interventions among excessive drinkers. British Journal of Addiction.
Rollnick, S., and Miller, W.R. (1995). What is motivational interviewing?. Behavioral and Cognitive Psychotherapy.
Romelsjo, A.; Andersson, L.; Barrner, H.; Borg, S.; Granstrand, C.; Hultman, O.; Hassler, A.; Kallqvist, A.; Magnusson, P.; Morgell, R.; Hyman, K.; Olofsson, A.; Olsson, E.; Rhedin, A.; and Wikblad, O. (1989). Randomized study of secondary prevention of early stage problem drinkers in primary health care. British Journal of Addiction.
Rowe, D., and Grills, C. (1993). African-centered drug treatment: An alternative conceptual paradigm for drug counseling with African-American clients. Journal of Psychoactive Drugs.
Ryan, R.M.; Plant, R.W.; and O'Malley, S. (1995). Initial motivations for alcohol treatment: Relations with patient characteristics, treatment involvement, and dropout. Addictive Behaviors.
Samet, J.H., and O'Connor, P.G. (1998). Alcohol abusers in primary care: Readiness to change behavior. American Journal of Medicine.
Samet, J.H.; Rollnick, S.; and Barnes, H. (1996). Beyond CAGE: A brief clinical approach after detection of substance abuse. Archives of Internal Medicine.
Sannibale, C. (1988). The differential effect of a set of brief interventions on the functioning of a group of "early-stage" problem drinkers. Australian Drug and Alcohol Review.
Satterfield, J.M. (1994). Integrating group dynamics and cognitive-behavioral groups: A hybrid model. Clinical Psychology: Science and Practice.
Saunders, B.; Wilkinson, C.; and Allsop, S. Motivational intervention with heroin users attending a methadone clinic. In: Miller, W.R., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991. pp. 279-292.
Saunders, B.; Wilkinson, C.; and Phillips, M. (1995). The impact of a brief motivational intervention with opiate users attending a methadone programme. Addiction.
Scales, R. (1998). "Motivational interviewing and skills-based counseling in cardiac rehabilitation: The Cardiovascular Health Initiative and Lifestyle Intervention (CHILE) Study." Ph.D. diss., University of New Mexico. Dissertation Abstracts International.
Schafer, J., and Brown, S.A. (1991). Marijuana and cocaine effect expectancies and drug use patterns. Journal of Consulting and Clinical Psychology.
Senft, R.A.; Polen, M.R.; Freeborn, D.K.; and Hollis, J.F. (1997). Brief intervention in a primary care setting for hazardous drinkers. American Journal of Preventive Medicine.
Silverman, K.; Chutuape, M.D.; Bigelow, G.E.; and Stitzer, M.L. Reinforcement of cocaine abstinence in treatment-resistant patients: Effects of reinforcer magnitude. In: Harris, L.S., ed. Problems of Drug Dependence, 1996. NIDA Research Monograph Series, Number 174. DHHS Pub. No. (ADM) 97-4236, Rockville, MD: National Institute on Drug Abuse, 1997. p. 74.
Silverman, K.; Higgins, S.T.; Brooner, R.K.; Montoya, I.D.; Cone, E.J.; Schuster, C.R.; and Preston, K.L. (1996). Sustained cocaine abstinence in methadone maintenance patients through voucher-based reinforcement therapy. Archives of General Psychiatry.
Simpson, D.D., and Joe, G.W. (1993). Motivation as a predictor of early dropout from drug abuse treatment. Psychotherapy.
Simpson, D.D.; Joe, G.W.; and Brown, B.S. (1997). Treatment retention and follow-up outcomes in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behaviors 11:294-307.
Sisson, R.W., and Azrin, N.H. (1986). Family member involvement to initiate and promote treatment of problem drinkers. Journal of Behavior Therapy and Experimental Psychiatry.
Sklar, S.M.; Annis, H.M.; and Turner, N.E. (1997). Development and validation of the Drug-Taking Confidence Questionnaire: A measure of coping self-efficacy. Addictive Behaviors: An International Journal.
Skutle, A., and Berg, G. (1987). Training in controlled drinking for early-stage problem drinkers. British Journal of Addiction.
Smith, D.E.; Heckemeyer, C.M.; Kratt, P.P.; and Mason, D.A. (1997). Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM: A pilot study. Diabetes Care.
Sobell, L.C. (1996). Bridging the gap between science and practitioners: The challenge before us. Behavior Therapy.
Sobell, L.C.; Breslin, F.C.; and Sobell, M.B. Substance-related disorders (alcohol). In: Turner, S., and Hersen, M., eds. Adult Psychopathology and Diagnostic Issues, 3rd ed. New York: John Wiley and Sons, 1997. pp. 128-159.
Sobell, L.C.; Cunningham, J.A.; and Sobell, M.B. (1996). Recovery from alcohol problems with and without treatment: Prevalence in two population surveys. American Journal of Public Health.
Sobell, L.C.; Cunningham, J.A.; Sobell, M.B.; Agrawal, S.; Gavin, D.R.; Leo, G.I.; and Singh, K.N. (1996). Fostering self-change among problem drinkers: A proactive community intervention. Addictive Behaviors.
Sobell, L.C., and Sobell, M.B, eds. Alcohol consumption measures. In: Allen, J.P., and Columbus, M., eds. Assessing Alcohol Problems: A Guide for Clinicians and Researchers. Treatment Handbook Series 4. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1995a. pp. 55-74.
Sobell, L.C., and Sobell, M.B. Timeline Follow Back (TLFB). Toronto, ON: Addiction Research Foundation, 1996.
Sobell, L.C.; Sobell, M.B.; Brown, J.; and Cleland, P.A. (1995). "A randomized trial comparing group versus individual guided self-change treatment for alcohol and drug abusers." Poster presented at the 29th Annual Meeting of the Association for Advancement of Behavior Therapy, Washington, DC.
Sobell, L.C.; Sobell, M.B.; and Leo, G.I. (1993a). "Spousal social support: A motivational intervention for alcohol abusers." Poster presented at the annual meeting of the Association for the Advancement of Behavior Therapy, Atlanta, GA.
Sobell, L.C.; Sobell, M.B.; Toneatto, T.; and Leo, G.I. (1993). What triggers the resolution of alcohol problems without treatment?. Alcoholism: Clinical and Experimental Research.
Sobell, L.C.; Toneatto, T.; and Sobell, M.B. (1994). Behavioral assessment and treatment planning for alcohol, tobacco, and other drug problems: Current status with an emphasis on clinical applications. Behavior Therapy.
Sobell, M.B.; Buchan, G.; and Sobell, L.C. (1996c). "Relationship of goal choices by substance abusers in guided self-change treatment to subject characteristics and treatment outcome." Poster presented at the annual meeting of the Association for Advancement of Behavior Therapy, New York.
Sobell, M.B., and Sobell, L.C. Problem Drinkers: Guided Self-Change Treatment. New York: Guilford Press, 1993.
Sobell, M.B., and Sobell, L.C. (1995b). "Group versus individual guided self-change treatment for problem drinkers." Paper presented at the World Congress on Behavioral and Cognitive Therapies, Copenhagen, Denmark.
Sobell, M.B., and Sobell, L.C. Guiding self-change. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors, 2nd ed. New York: Plenum, 1998. pp. 189-202.
Sobell, M.B., and Sobell, L.C. Stepped care for alcohol problems: An efficient method for planning and delivering clinical services. In: Tucker, J.A.; Donovan, D.M.; and Marlatt, G.A., eds. Changing Addictive Behavior: Bridging Clinical and Public Health Strategies. New York: Guilford Press, 1999. pp. 331-343.
Southwick, L.; Steele, C.; Marlatt, A.; and Lindell, M. (1981). Alcohol-related expectancies: Defined by phase of intoxication and drinking experience. Journal of Consulting and Clinical Psychology.
Stanton, M.D. The role of family and significant others in the engagement and retention of drug-dependent individuals. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug-Dependent Individual in Treatment. NIDA Research Monograph Series, Number 165. DHHS Pub. No. (ADM) 97-4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 157-180.
Stephens, R.S.; Roffman, R.A.; Cleaveland, B.L.; Curtin, L.; and Wertz, J. (1994). "Extended versus minimal intervention with marijuana-dependent adults." Paper presented at the annual meeting of the Association for Advancement of Behavior Therapy, San Diego, CA.
Strang, J.; Bacchus, L.; Howes, S.; and Watson, P. (1997). Turned away from treatment: Maintenance-seeking opiate addicts at two-year follow-up. Addiction Research.
Sutton, S. Can stages of change provide guidelines in the treatment of addictions? In: Edwards, G., and Dare, C., eds. Psychotherapy, Psychological Treatments and the Addictions. New York: Cambridge University Press, 1996.
Swanson, A.J.; Pantalon, M.V.; and Cohen, K.R. (in press). Motivational interviewing and treatment adherence among psychiatric and dually-diagnosed patients. Journal of Nervous and Mental Disease.
Taleff, M.J. A Handbook To Assess and Treat Resistance in Chemical Dependency. Dubuque, IA: Kendall/Hunt, 1997.
Thomas, E.J., and Ager, R.D. Unilateral family therapy with spouses of uncooperative alcohol abusers. In: O'Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 3-33.
Thombs, D.L. Introduction to Addictive Behaviors. New York: Guilford Press, 1994.
Tonigan, J.S.; Toscova, R.T.; and Connors, G.J. Spirituality and the 12-Step programs: A guide for clinicians. In: Miller, W.R., ed. Integrating Spirituality Into Treatment: Resources for Practitioners. Washington, DC: American Psychological Association, 1999.
Trigwell, P.; Grant, P.J.; and House, A. (1997). Motivation and glycemic control in diabetes mellitus. Journal of Psychosomatic Research.
Truax, C.B., and Carkhuff, R.R. Toward Effective Counseling and Psychotherapy. Chicago: Aldine, 1967.
Tuchfield, B. (1981). Spontaneous remission in alcoholics: Empirical observations and theoretical implications. Journal of Studies on Alcohol.
Tucker, J.A. (1995). Predictors of help-seeking and the temporal relationship of help to recovery among treated and untreated recovered problem drinkers. Addiction.
Tucker, J.A.; Vuchinich, R.E.; and Gladsjo, J.A. (1994). Environmental events surrounding natural recovery from alcohol-related problems. Journal of Studies on Alcohol.
Tucker, J.A.; Vuchinich, R.E.; and Pukish, M.M. Molar environmental contexts surrounding recovery from alcohol problems by treated and untreated problem drinkers. In: Marlatt, G.A., and Vanden Bos, G.R., eds. Addictive Behaviors: Readings on Etiology, Prevention, and Treatment. Washington, DC: American Psychological Association, 1997. pp. 581-601.
Vaillant, G.E. The Natural History of Alcoholism Revisited. Cambridge, MA: Harvard University Press, 1995.
Van Bilsen, H.P. Motivational interviewing: perspectives from the Netherlands with particular emphasis on heroin-dependent clients. In: Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991. pp. 214-235.
Van Bremen, J.R., and Chasnoff, I.J. (1994). Policy issues for integrating parenting interventions and addiction treatment for women. Topics in Early Childhood Special Education.
Varney, S.M.; Rohsenow, D.J.; Dey, A.N.; Myers, M.G.; Zwick, W.R.; and Monti, P.M. (1995). Factors associated with help seeking and perceived dependence among cocaine users. American Journal of Drug and Alcohol Abuse.
Victorio-Estrada, A., and Mucha, R.F. (1997). The Inventory of Drinking Situations (IDS) in current drinkers with different degrees of alcohol problems. Addictive Behaviors.
Wagner, C.C.; Ingersoll, K.S.; Horvatich, P.; May, J.; Fornili, K.; and Gharib, S. A Technology Transfer Case Study: Part II. Motivational Enhancement Therapy as First Stage Treatment. Scottsdale, AZ: College on Problems of Drug Dependence, 1998.
Wahlberg, J. Personal growth and self-esteem through cultural spiritualism: A Native-American experience. In: Rivas, R.F., and Hull, G.H., eds. Case Studies in Generalist Practice. Belmont, CA: Wadsworth, 1996. pp. 65-71.
Wallace, J. (1990). The new disease model of alcoholism. Western Journal of Medicine.
Wallace, P.; Cutler, S.; and Haines, A. (1988). Randomized controlled trial of general practitioner intervention in patients with excessive alcohol consumption. British Medical Journal.
Walters, S.T.; Bennett, M.E.; and Miller, J.E. Reducing alcohol use in college students: A controlled trial of two brief interventions. Journal of Drug Education.
Watson, A.L., and Sher, K.J. (1998). Resolution of alcohol problems without treatment: Methodological issues and future directions of natural recovery research. Clinical Psychology: Science and Practice.
Wetter, D.W.; Fiore, M.C.; Gritz, E.R.; Lando, H.A.; Stitzer, M.L.; Hasselblad, V.; and Baker, T.B. (1998). The Agency for Health Care Policy and Research: Smoking cessation clinical practice guideline-Findings and implications for psychologists. American Psychologist.
Wilbanks, W.L. Drug addiction should be treated as a lack of self-discipline. In: Leone, B., ed. Chemical Dependency: Opposing Viewpoints. San Diego, CA: Greenhaven, 1989.
Wilk, A.I.; Jensen, N.M.; and Havighurst, T.C. (1997). Meta-analysis of randomized control trials addressing brief interventions in heavy alcohol drinkers. Journal of General Internal Medicine.
Williams, R., and Williams, V. Anger Kills: Seventeen Strategies for Controlling the Hostility That Can Harm Your Health. New York: HarperCollins, 1994.
Yahne, C.E., and Miller, W.R. Evoking hope. In: Miller, W.R., ed. Integrating Spirituality Into Treatment: Resources for Practitioners. Washington, DC: American Psychological Association, 1999.
Zacny, J.P.; Divane, W.T.; and de Wit, H. (1992). Assessment of magnitude and availability of a non-drug reinforcer on preference for a drug reinforcer. Human Psychopharmacology.
Ziedonis, D., and Fisher, W. (1996). Motivation-based assessment and treatment of substance abuse in patients with schizophrenia. Directions in Psychiatry.
Zweben, A., and Barrett, D. Brief couples treatment for alcohol problems. In: O'Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 353-380.
Zweben, A.; Bonner, M.; Chaim, G.; and Santon, P. (1988). Facilitative strategies for retaining the alcohol-dependent client in outpatient treatment. Alcoholism Treatment Quarterly.
Zweben, A., and Fleming, M.F. Brief interventions for alcohol and drug problems. In: Tucker, J.A.; Donovan, D.M.; and Marlatt, G.A., eds. Changing Addictive Behavior. New York: Guilford Press, in press.
Zweben, A., and Li, S. (1981). Efficacy of role induction in preventing early dropout from outpatient treatment of drug dependency. American Journal of Drug and Alcohol Abuse.
Zweben, A.; Pearlman, S.; and Li, S. (1988). A comparison of brief advice and conjoint therapy in the treatment of alcohol abuse: The results of the Marital Systems Study. British Journal of Addiction.
Zweben, J.E. (1991). Counseling issues in methadone maintenance treatment. Journal of Psychoactive Drugs.