# Appendix E --Field Reviewers

- Noel Brankenhoff, L.M.F.T., L.C.D.P.
- Child and Family Services
- Middletown, Rhode Island

- Rodolfo Briseno, L.C.D.C.
- Coordinator for Cultural/Special Populations and Youth Treatment
- Program Services, Program Initiatives
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Richard L. Brown, M.D., M.P.H.
- Associate Professor
- Department of Family Medicine
- University of Wisconsin School of Medicine
- Madison, Wisconsin

- Michael Burke
- Senior Substance Abuse Specialist
- Student Health
- Rutgers University
- New Brunswick, New Jersey

- Kate Carey, Ph.D.
- Associate Professor
- Department of Psychology
- Syracuse University
- Syracuse, New York

- Anthony J. Cellucci, Ph.D.
- Director of Idaho State University Clinic
- Associate Professor of Psychology
- Idaho State University
- Pocatello, Idaho

- Gerard Connors, Ph.D.
- Research Institute on Alcoholism
- 1021 Main Street
- Buffalo, New York

- John Cunningham, Ph.D.
- Scientist
- Addiction Research Foundation Division
- Centre for Addiction and Mental Health
- Toronto, Ontario

- Janie Dargan, M.S.W.
- Senior Policy Analyst
- Office of National Drug Control Policy/EOP
- Washington, D.C.

- George De Leon, Ph.D.
- Center for Theraputic Community Research
- New York, New York

- Nereida Diaz-Rodriguez, L.L.M., J.D.
- Project Director
- Director to the Master in Health Science in Substance Abuse
- Centro de Entudion on Adiccion (Altos Salud Mental)
- Edif. Hosp. Regional de Bayamon
- Santa Juanita, Bayamon, Puerto Rico

- Thomas Diklich, B.A.
- Portsmouth CSR
- Portsmouth, Virginia

- Chris Dunn, Ph.D., M.A.C., C.D.C.
- Psychologist
- University of Washington
- Psychiatry and Behavioral Science
- Seattle, Washington

- Madeline Dupree, L.P.C.
- Harrisonburg-Rockingham CSB
- Harrisonburg, Virginia

- Gary L. Fisher, Ph.D.
- Nevada Addiction Technology Transfer Center
- College of Education
- University of Nevada at Reno
- Reno, Nevada

- Cynthia Flackus, M.S.W., L.I.C.S.W.
- Therapist
- Camp Share Renewal Center
- Walker, Minnesota

- Stephen T. Higgins, Ph.D.
- Professor
- Departments of Psychiatry and Psychology
- University of Vermont
- Burlington, Vermont

- Col. Kenneth J. Hoffman, M.D., M.P.H., M.C.F.S.
- Preventive Medicine Consultant
- HHC 18th Medical Command
- Seoul, Korea

- James Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- Ron Jackson, M.S.W.
- Executive Director
- Evergreen Treatment Services
- Seattle, Washington

- Linda Kaplan
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Matthew Kelly, Ph.D.
- Clinical Director
- Robert Wood Johnson Foundation
- Northwest Mexico Fighting Back, Inc.
- Gallup, New Mexico

- Karen Kelly-Woodall, M.S., M.A.C., N.C.A.C.II
- Criminal Justice Coordinator
- Cork Institute
- Morehouse School of Medicine
- Atlanta, Georgia

- Richard Laban, Ph.D.
- Laban's Training
- Harrisburg, Pennsylvania

- Lauren Lawendowski, Ph.D.
- Acting Project Director
- Center on Alcoholism, Substance Abuse, and Addiction
- University of New Mexico
- Albuquerque, New Mexico

- Bruce R. Lorenz, N.C.A.C. II
- Director
- Thresholds, Inc.
- Dover, Delaware

- Russell P. MacPherson, Ph.D., C.A.P., C.A.P.P., C.C.P., D.A.C., D.V.C.
- President
- RPM Addiction Prevention Training
- Deland, Florida

- George Medzerian, Ph.D.
- Pensacola, Florida

- Lisa A. Melchior, Ph.D.
- Vice President
- The Measurement Group
- Culver City, California

- Paul Nagy, M.S., C.S.A.C.
- Director
- Duke Alcoholism and Addictions Program
- Duke University Medical Center
- Durham, North Carolina

- Tracy A. O'Leary, Ph.D.
- Clinical Supervisor
- Assistant Project Coordinator
- Center for Alcohol and Addiction Studies
- Brown University
- Providence, Rhode Island

- Gwen M. Olitsky, M.S.
- CEO
- The Self-Help Institute for Training and Therapy
- Lansdale, Pennsylvania

- Michele A. Packard, Ph.D.
- Executive Director
- SAGE Institute
- Training and Consulting
- Boulder, California

- Michael Pantalon, Ph.D.
- Yale School of Medicine
- New Haven, Connecticut

- Joe Pereira, L.I.C.S.W., C.A.S.
- Recovery Strategies
- Medford, Massachusetts

- Harold Perl, Ph.D.
- Public Health Analyst
- Division of Clinical and Prevention Research
- National Institute on Alcoholism and Alcohol Abuse
- Bethesda, Maryland

- Raul G. Rodriguez, M.D.
- Medical Director
- La Hacienda Treatment Center
- Hunt, Texas

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Suzan Swanton, M.S.W.
- Clinical Director
- R.E.A.C.H. Mobile Home Services
- Baltimore, Maryland

- Michael J. Taleff, Ph.D., C.A.C., M.A.C., N.C.A.C.II
- Assistant Professor and Coordinator
- Graduate Programs in Chemical Dependency Counselor Education
- Department of Counselor Education
- Counseling Psychology and Rehabilitation Services
- Pennsylvania State University
- University Park, Pennsylvania

- Nola C. Veazie, Ph.D., L.P.C., C.A.D.A.C.
- Superintendent
- Medical Services Department
- United States Air Force
- Family Therapist/Drug and Alcohol Counselor
- Veazie Family Therapy
- Santa Maria, California

- Mary Velasquez, Ph.D.
- Psychology Department
- University of Houston
- Houston, Texas

- Christopher Wagner, Ph.D.
- Division of Substance Abuse Medicine
- Virginia Commonwealth University
- Richmond, Virginia