# Appendix D—Resource Panel

- Peter J. Cohen, M.D., J.D.
- Adjunct Professor of Law
- Georgetown University Law Center
- Washington, D.C.

- Frances Cotter, M.A., M.P.H.
- Senior Public Health Advisor
- Office of Managed Care
- Center for Substance Abuse and Treatment
- Rockville, Maryland

- Dorynne Czechowicz, M.D.
- Associate Director
- Division of Clinical and Services Research
- Treatment Research Branch
- National Institute on Drug Abuse
- Bethesda, Maryland

- Gil Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Linda Kaplan
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Pedro Morales, J.D.
- Director
- Equal Employment Civil Rights
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Harold I. Perl, Ph.D.
- Public Health Analyst
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland

- Barbara J. Silver, Ph.D.
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Department of Health and Human Services
- Rockville, Maryland

- Lucretia Vigil
- Policy Advisor
- National Coalition of Hispanic Health and Human Services Organization (COSSMO)
- Washington, D.C.