# Appendix B—Screening and Assessment Instruments

This appendix includes

- Alcohol and Drug Consequences Questionnaire (ADCQ)
- Alcohol (and Illegal Drugs) Decisional Balance Scale
- Alcohol Effects Questionnaire
- Alcohol Expectancy Questionnaire--III (Adult)
- Alcohol Use Disorders Identification Test (AUDIT)
- Brief Situational Confidence Questionnaire (BSCQ)
- Personal Feedback Report
- Understanding Your Personal Feedback Report
- Readiness To Change Questionnaire (Treatment Version) (RCQ-TV)
- Situational Confidence Questionnaire (SCQ-39)
- Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A, 8D)
- University of Rhode Island Change Assessment Scale (URICA)
- What I Want From Treatment

Ordering information for these instruments, along with other resources, appears in Appendix C.

## Alcohol and Drug Consequences Questionnaire (ADCQ)

There can be good and bad consequences to any change. These consequences may not be the same for everyone. In thinking about your decision to change your alcohol or drug use, we would like to know what consequences are important to you. This is not a test: There are no right or wrong answers. We simply want to know what you think.

My primary problem drug is (write in name of primary drug, e.g. alcohol, cocaine) ____________________________________________________

All questions below refer to my primary drug use.

When I consider stopping or cutting down my primary drug use, the following reasons are important to me.

"IF I STOP OR CUT DOWN ...."

### Alcohol and Drug Consequences Questionnaire (ADCQ)

Alcohol and Drug Consequences Questionnaire (ADCQ)

Alcohol and Drug Consequences Questionnaire (ADCQ)

| | Circle the number which applies to you.
| | Not Important | Slightly Important | Moderately Important | Very Important | Extremely Important | Not Applicable
1. | I will feel better physically. | 1 | 2 | 3 | 4 | 5 | 0
2. | I will have difficulty relaxing. | 1 | 2 | 3 | 4 | 5 | 0
3. | I will change a lifestyle I enjoy. | 1 | 2 | 3 | 4 | 5 | 0
4. | I will have fewer problems with my family. | 1 | 2 | 3 | 4 | 5 | 0
5. | I will feel frustrated and anxious. | 1 | 2 | 3 | 4 | 5 | 0
6. | I will have more money to do other things with. | 1 | 2 | 3 | 4 | 5 | 0
7. | I will be more active and alert. | 1 | 2 | 3 | 4 | 5 | 0
8. | I will get depressed. | 1 | 2 | 3 | 4 | 5 | 0
9. | I will have fewer problems with friends. | 1 | 2 | 3 | 4 | 5 | 0
10. | I will feel better about myself. | 1 | 2 | 3 | 4 | 5 | 0
11. | I will regain some self-respect. | 1 | 2 | 3 | 4 | 5 | 0
12. | I will accomplish more of the things I want to get done. | 1 | 2 | 3 | 4 | 5 | 0
13. | I will have a better relationship with my family. | 1 | 2 | 3 | 4 | 5 | 0
14. | I will have difficulty coping with my problems. | 1 | 2 | 3 | 4 | 5 | 0
15. | I will feel withdrawal or craving. | 1 | 2 | 3 | 4 | 5 | 0
16. | I will have too much time on my hands. | 1 | 2 | 3 | 4 | 5 | 0
17. | I will have difficulty not drinking or using drugs. | 1 | 2 | 3 | 4 | 5 | 0
18. | My health will improve. | 1 | 2 | 3 | 4 | 5 | 0
19. | I will live longer. | 1 | 2 | 3 | 4 | 5 | 0
20. | I will be more in control of life. | 1 | 2 | 3 | 4 | 5 | 0
21. | I will feel bored. | 1 | 2 | 3 | 4 | 5 | 0
22. | I will be irritable. | 1 | 2 | 3 | 4 | 5 | 0
23. | I will be more financially stable. | 1 | 2 | 3 | 4 | 5 | 0
24. | I will miss the taste. | 1 | 2 | 3 | 4 | 5 | 0
25. | I will have a better relationship with my friends. | 1 | 2 | 3 | 4 | 5 | 0
26. | I will feel stressed out. | 1 | 2 | 3 | 4 | 5 | 0
27. | I will save more money. | 1 | 2 | 3 | 4 | 5 | 0
28. | I will miss the feeling of being high. | 1 | 2 | 3 | 4 | 5 | 0

## Alcohol (and Illegal Drugs) Decisional Balance Scale

Alcohol (and Illegal Drugs) Decisional Balance Scale

Alcohol (and Illegal Drugs) Decisional Balance Scale

Client ID# ______________ Date: _____/_____/_____ Assessment Point: ______________
THE FOLLOWING STATEMENTS MAY PLAY A PART IN MAKING A DECISION ABOUT USING ALCOHOL (AND DRUGS). WE WOULD LIKE TO KNOW HOW IMPORTANT EACH STATEMENT IS TO YOU AT THE PRESENT TIME IN RELATION TO MAKING A DECISION TO EACH STATEMENT ON THE FOLLOWING 5 POINTS:
1 = Not important at all 2 = Slightly important 3 = Moderately important 4 = Very important 5 = Extremely important
PLEASE READ EACH STATEMENT AND CIRCLE THE NUMBER ON THE RIGHT TO INDICATE HOW YOU RATE ITS LEVEL OF IMPORTANCE AS IT RELATES TO YOUR MAKING A DECISION ABOUT WHETHER TO DRINK (OR USE DRUGS)AT THE PRESENT TIME.
How important is this to me? | | Importance in making a decision about drinking:
| | Not At All | Slightly | Moderately | Very | Extremely
1. | My drinking (drug use) causes problems with others. | 1 | 2 | 3 | 4 | 5
2. | I like myself better when I am drinking (using drugs). | 1 | 2 | 3 | 4 | 5
3. | Because I continue to drink (use drugs) some people think I lack the character to quit. | 1 | 2 | 3 | 4 | 5
4. | Drinking (drug use) helps me deal with problems. | 1 | 2 | 3 | 4 | 5
5. | Having to lie to others about my drinking (drug use) bothers me. | 1 | 2 | 3 | 4 | 5
6. | Some people try to avoid me when I drink (use drugs). | 1 | 2 | 3 | 4 | 5
7. | Drinking (drug use) helps me to have fun and socialize. | 1 | 2 | 3 | 4 | 5
8. | Drinking (drug use) interferes with my functioning at home or/and at work. | 1 | 2 | 3 | 4 | 5
9. | Drinking (drug use) makes me more of a fun person. | 1 | 2 | 3 | 4 | 5
10. | Some people close to me are disappointed in me because of my drinking (drug use). | 1 | 2 | 3 | 4 | 5
11. | Drinking (drug use) helps me to loosen up and express myself. | 1 | 2 | 3 | 4 | 5
12. | I seem to get myself into trouble when drinking (using drugs). | 1 | 2 | 3 | 4 | 5
13. | I could accidentally hurt someone because of my drinking (drug use). | 1 | 2 | 3 | 4 | 5
14. | Not drinking (using drugs) at a social gathering would make me feel too different. | 1 | 2 | 3 | 4 | 5
15. | I am losing the trust and respect of my coworkers and/or spouse because of my drinking (drug use). | 1 | 2 | 3 | 4 | 5
16. | My drinking (drug use) helps give me energy and keeps me going. | 1 | 2 | 3 | 4 | 5
17. | I am more sure of myself when I am drinking (using drugs). | 1 | 2 | 3 | 4 | 5
18. | I am setting a bad example for others with my drinking (drug use). | 1 | 2 | 3 | 4 | 5
19. | Without alcohol (illegal drugs), my life would be dull and boring. | 1 | 2 | 3 | 4 | 5
20. | People seem to like me better when I am drinking (using drugs). | 1 | 2 | 3 | 4 | 5
Scoring: Pros of drinking (drug use) are items: 2, 4, 7, 9, 11, 14, 16, 17, 19, 20. Cons of drinking (drug use) are items: 1, 3, 5, 6, 8, 10, 12, 13, 15, 18. To get the average number of pros endorsed, add up the total number of points from the items and divide by 10. Example: Pros of drinking (drug use) = Sum of items (2+4+7+9+11+14+16+17+19+20) divided by 10. To get the average number of cons endorsed, add up the total number of points from the items and divide by 10. Example: Cons of drinking (drug use) = Sum of items (1+3+5+6+8+10+12+13+15+18) divided by 10.

## Alcohol Effects Questionnaire

Alcohol Effects Questionnaire

Alcohol Effects Questionnaire

This questionnaire consists of a series of statements that describe possible effects following alcohol use. We would like to find out about your present beliefs about alcohol. Please read each of the statements and respond according to your experiences with a heavy (5 drinks or more per occasion) amount of alcohol. If you believe alcohol sometimes or always has the stated effect on you, check AGREE. If you believe alcohol never has the stated effect on you, check DISAGREE. Then, in the column to the far right, fill in the number that best corresponds to the strength of your belief, according to the following scale: 1 = Mildly Believe 10 = Strongly Believe For example, if you strongly believe that alcohol makes you more intelligent, you would check AGREE and enter a "10" in thefar column. Please answer every questionwithout skipping any. For a HEAVY (5 or more drinks per occasion) amount of alcohol
| | Agree | Disagree | Strength of Belief
1. | Drinking makes me feel flushed. | ____ | ____ | ____
2. | Alcohol decreases muscular tension in my body. | ____ | ____ | ____
3. | Drinking makes me feel less shy. | ____ | ____ | ____
4. | Alcohol enables me to fall asleep much more easily. | ____ | ____ | ____
5. | I feel powerful when I drink, as if I can really influence others to do what I want. | ____ | ____ | ____
6. | I'm more clumsy after I drink. | ____ | ____ | ____
7. | I'm more romantic when I drink. | ____ | ____ | ____
8. | Drinking makes the future seem brighter to me. | ____ | ____ | ____
9. | If I have had alcohol it is easier for me to tell someone off. | ____ | ____ | ____
10. | I can't act as quickly when I've been drinking. | ____ | ____ | ____
11. | Alcohol can act as an anesthetic for me; that is, it can deaden the pain. | ____ | ____ | ____
12. | I often feel sexier after I've been drinking. | ____ | ____ | ____
13. | Drinking makes me feel good. | ____ | ____ | ____
14. | Alcohol makes me careless about my actions. | ____ | ____ | ____
15. | Alcohol has a pleasant, cleansing, tingly taste to me. | ____ | ____ | ____
16. | Drinking increases my aggressiveness. | ____ | ____ | ____
17. | Alcohol seems like magic to me. | ____ | ____ | ____
18. | Alcohol makes it hard for me to concentrate. | ____ | ____ | ____
19. | After drinking, I'm a better lover. | ____ | ____ | ____
20. | When I'm drinking, it is easier to open up and express my feelings. | ____ | ____ | ____
21. | Drinking adds a certain warmth to social occasions for me. | ____ | ____ | ____
22. | If I'm feeling restricted in any way, drinking makes me feel better. | ____ | ____ | ____
23. | I can't think as quickly after I drink. | ____ | ____ | ____
24. | Having drinks is a nice way for me to celebrate special occasions. | ____ | ____ | ____
25. | Alcohol makes me worry less. | ____ | ____ | ____
26. | Drinking makes me inefficient. | ____ | ____ | ____
27. | Drinking is pleasurable because it's enjoyable for me to join in with other people who are enjoying themselves. | ____ | ____ | ____
28. | After drinking, I am more sexually responsive. | ____ | ____ | ____
29. | I feel more coordinated after I drink. | ____ | ____ | ____
30. | I'm more likely to say embarrassing things after drinking. | ____ | ____ | ____
31. | I enjoy having sex more if I've had alcohol. | ____ | ____ | ____
32. | I'm more likely to get into an argument if I've had alcohol. | ____ | ____ | ____
33. | Alcohol makes me less concerned about doing things well. | ____ | ____ | ____
34. | Alcohol helps me sleep better. | ____ | ____ | ____
35. | Drinking gives me more confidence in myself. | ____ | ____ | ____
36. | Alcohol makes me more irresponsible. | ____ | ____ | ____
37. | After drinking it is easier for me to pick a fight. | ____ | ____ | ____
38. | Alcohol makes it easier for me to talk to people. | ____ | ____ | ____
39. | If I have alcohol it is easier for me to express my feelings. | ____ | ____ | ____
40. | Alcohol makes me more interesting. | ____ | ____ | ____

## Alcohol Expectancy Questionnaire--III (Adult)

Alcohol Expectancy Questionnaire--III (Adult)

Alcohol Expectancy Questionnaire--III (Adult)

The following pages contain statements about the effects of alcohol. Read each statement carefully and respond according to your own personal thoughts, feelings, and beliefs about alcohol now. We are interested in what you think about alcohol, regardless of what other people might think. If you think that the statement is true, or mostly true, or true some of the time, then mark (X) "Agree" on the answer sheet. If you think the statement is false, or mostly false, then mark (X) "Disagree" on the answer sheet. When the statements refer to drinking alcohol you may think in terms of drinking any alcoholic beverage, such as beer, wine, whiskey, liquor, rum, scotch, vodka, gin, or various alcoholic mixed drinks. Whether or not you have had actual drinking experiences yourself, you are to answer in terms of your beliefs about alcohol. It is important that you respond to every question. PLEASE BE HONEST. REMEMBER, YOUR ANSWERS ARE CONFIDENTIAL. RESPOND TO THESE ITEMS ACCORDING TO WHAT YOU PERSONALLY BELIEVE TO BE TRUE ABOUT ALCOHOL
(Mark "X" according to your beliefs) | | Agree | Disagree
1. | Alcohol can transform my personality. | ______ | ______
2. | Drinking helps me feel whatever way I want to feel. | ______ | ______
3. | Some alcohol has a pleasant, cleansing, tingly taste. | ______ | ______
4. | Alcohol makes me feel happy. | ______ | ______
5. | Drinking adds a certain warmth to social occasions. | ______ | ______
6. | Sweet mixed drinks taste good. | ______ | ______
7. | When I am drinking, it is easier to open up and express my feelings. | ______ | ______
8. | Time passes quickly when I am drinking. | ______ | ______
9. | When they drink, women become more sexually relaxed. | ______ | ______
10. | Drinking makes me feel flushed. | ______ | ______
11. | I feel powerful when I drink, as if I can really influence others to do as I want. | ______ | ______
12. | Drinking increases male aggressiveness. | ______ | ______
13. | Alcohol lets my fantasies flow more easily. | ______ | ______
14. | Drinking gives me more confidence in myself. | ______ | ______
15. | Drinking makes me feel good. | ______ | ______
16. | I feel more creative after I have been drinking. | ______ | ______
17. | Having a few drinks is a nice way to celebrate special occasions. | ______ | ______
18. | I can discuss or argue a point more forcefully after I have had a few drinks. | ______ | ______
19. | When I am drinking, I feel free to be myself and to do whatever I want. | ______ | ______
20. | Drinking makes it easier to concentrate on the good feelings I have at the time. | ______ | ______
21. | Alcohol allows me to be more assertive. | ______ | ______
22. | When I feel "high" from drinking, everything seems to feel better. | ______ | ______
23. | A drink or two makes the humorous side of me come out. | ______ | ______
24. | If I am nervous about having sex, alcohol makes me feel better. | ______ | ______
25. | Drinking relieves boredom. | ______ | ______
26. | I find that conversing with members of the opposite sex is easier for me after I have had a few drinks. | ______ | ______
27. | After a few drinks, I feel less sexually inhibited. | ______ | ______
28. | Drinking is pleasurable because it is enjoyable to join in with people who are enjoying themselves. | ______ | ______
29. | I like the taste of some alcoholic beverages. | ______ | ______
30. | If I am feeling restricted in any way, a few drinks make me feel better. | ______ | ______
31. | Men are friendlier when they drink. | ______ | ______
32. | It is easier for me to meet new people if I've been drinking. | ______ | ______
33. | After a few drinks it is easier to pick a fight. | ______ | ______
34. | Alcohol can eliminate feelings of inferiority. | ______ | ______
35. | Alcohol makes women more sensuous. | ______ | ______
36. | If I have a couple of drinks, it is easier to express my feelings. | ______ | ______
37. | I feel less bothered by physical ills after a few drinks. | ______ | ______
38. | Alcohol makes me need less attention from others than I usually do. | ______ | ______
39. | Alcohol makes me more outspoken or opinionated. | ______ | ______
40. | After a few drinks, I feel more self-reliant than usual. | ______ | ______
41. | After a few drinks, I don't worry as much about what other people think of me. | ______ | ______
42. | When drinking, I do not consider myself totally accountable or responsible for my behavior. | ______ | ______
43. | Alcohol enables me to have a better time at parties. | ______ | ______
44. | Anything that requires a relaxed style can be facilitated by alcohol. | ______ | ______
45. | Drinking makes the future seem brighter. | ______ | ______
46. | I am not as tense if I am drinking. | ______ | ______
47. | I often feel sexier after I have had a couple of drinks. | ______ | ______
48. | Having a few drinks helps me relax in a social situation. | ______ | ______
49. | I drink when I am feeling mad. | ______ | ______
50. | Drinking alone or with one other person makes me feel calm and serene. | ______ | ______
51. | After a few drinks, I feel brave and more capable of fighting. | ______ | ______
52. | Drinking can make me more satisfied with myself. | ______ | ______
53. | There is more camaraderie in a group of people who have been drinking. | ______ | ______
54. | My feelings of isolation and alienation decrease when I drink. | ______ | ______
55. | A few drinks make me feel less in touch with what is going on around me. | ______ | ______
56. | Alcohol makes me more tolerant of people I do not enjoy. | ______ | ______
57. | Alcohol helps me sleep better. | ______ | ______
58. | Drinking increases female aggressiveness. | ______ | ______
59. | I am a better lover after a few drinks. | ______ | ______
60. | Women talk more after they have had a few drinks. | ______ | ______
61. | Alcohol decreases muscular tension. | ______ | ______
62. | Alcohol makes me worry less. | ______ | ______
63. | A few drinks make it easier to talk to people. | ______ | ______
64. | After a few drinks, I am usually in a better mood. | ______ | ______
65. | Alcohol seems like magic. | ______ | ______
66. | Women can have orgasms more easily if they have been drinking. | ______ | ______
67. | At times, drinking is like permission to forget problems. | ______ | ______
68. | Drinking helps me get out of a depressed mood. | ______ | ______
69. | After I have had a couple of drinks, I feel I am more of a caring, sharing person. | ______ | ______
70. | Alcohol decreases my feelings of guilt about not working. | ______ | ______
71. | I feel more coordinated after I drink. | ______ | ______
72. | Alcohol makes me more interesting. | ______ | ______
73. | A few drinks make me feel less shy. | ______ | ______
74. | If I am tense or anxious, having a few drinks makes me feel better. | ______ | ______
75. | Alcohol enables me to fall asleep more easily. | ______ | ______
76. | If I am feeling afraid, alcohol decreases my fears. | ______ | ______
77. | A couple of drinks make me more aroused or physiologically excited. | ______ | ______
78. | Alcohol can act as an anesthetic; that is, it can deaden pain. | ______ | ______
79. | I enjoy having sex more if I have had some alcohol. | ______ | ______
80. | I am more romantic when I drink. | ______ | ______
81. | I feel more masculine/feminine after a few drinks. | ______ | ______
82. | When I am feeling antisocial, drinking makes me more gregarious. | ______ | ______
83. | Alcohol makes me feel better physically. | ______ | ______
84. | Sometimes when I drink alone or with one other person it is easy to feel cozy and romantic. | ______ | ______
85. | I feel like a more happy-go-lucky person when I drink. | ______ | ______
86. | Drinking makes get-togethers more fun. | ______ | ______
87. | Alcohol makes it easier to forget bad feelings. | ______ | ______
88. | After a few drinks, I am more sexually responsive. | ______ | ______
89. | If I am cold, having a few drinks will give me a sense of warmth. | ______ | ______
90. | It is easier to act on my feelings after I have had a few drinks. | ______ | ______
91. | I become lustful when I drink. | ______ | ______
92. | A couple of drinks make me feel more outgoing. | ______ | ______
93. | A drink or two can make me feel more wide awake. | ______ | ______
94. | Alcohol decreases my hostilities. | ______ | ______
95. | Alcohol makes me feel closer to people. | ______ | ______
96. | I tend to be less self-critical when I have something alcoholic to drink. | ______ | ______
97. | I find that conversing with members of the opposite sex is easier for me after I have had a few drinks. | ______ | ______
98. | Drinking makes me feel flushed. | ______ | ______
99. | It is easier to remember funny stories or jokes when I have been drinking. | ______ | ______
100. | After a few drinks, I am less submissive to those in positions of authority. | ______ | ______
101. | Alcohol makes me more talkative. | ______ | ______
102. | I am more romantic when I drink. | ______ | ______
103. | Men can have orgasms more easily if they have had a drink. | ______ | ______
104. | A drink or two is really refreshing after strenuous physical activity. | ______ | ______
105. | Alcohol enables me to have a better time at parties. | ______ | ______
106. | I can be more persuasive if I have had a few drinks. | ______ | ______
107. | Drinking makes people feel more at ease in social situations. | ______ | ______
108. | Alcohol helps me sleep better. | ______ | ______
109. | After a drink, things like muscle aches and pains do not hurt as much. | ______ | ______
110. | Women are friendlier after they have had a few drinks. | ______ | ______
111. | Alcohol makes me worry less. | ______ | ______
112. | Alcohol makes it easier to act impulsively or make decisions quickly. | ______ | ______
113. | Alcohol makes me feel less shy. | ______ | ______
114. | Alcohol makes me more tolerant of people I do not enjoy. | ______ | ______
115. | Alcohol makes me need less attention from others than I usually do. | ______ | ______
116. | A drink or two can slow me down, so I do not feel so rushed or pressured for time. | ______ | ______
117. | I feel more sexual after a few drinks. | ______ | ______
118. | Alcohol makes me feel better physically. | ______ | ______
119. | Having a drink in my hand can make me feel secure in a difficult social situation. | ______ | ______
120. | Things seem funnier when I have been drinking, or at least I laugh more. | ______ | ______

## Alcohol Use Disorders Identification Test (AUDIT)

Alcohol Use Disorders Identification Test (AUDIT)

Alcohol Use Disorders Identification Test (AUDIT)

Please answer each question by checking one of the circles in the second column.
Q1 | - Never; - Monthly or less; - 2-4 times per month; - 2-3 times per week; - 4+ times per week | How often do you have a drink containing alcohol?
Q2 | - 1 or 2; - 3 or 4; - 5 or 6; - 7 to 9; - 10 or more | How many drinks containing alcohol do you have on a typical day when you are drinking?
Q3 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often do you have six or more drinks on one occasion?
Q4 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often during the last year have you found that you were not able to stop drinking once you had started?
Q5 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often in the last year have you failed to do what was normally expected of you because you were drinking?
Q6 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session?
Q7 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often during the last year have you had a feeling of guilt or remorse about drinking?
Q8 | - Never; - Less than monthly; - Monthly; - Weekly; - Daily or almost daily | How often during the last year have you been unable to remember what happened the night before because you had been drinking?
Q9 | - No; - Yes, but not in the last year; - Yes, during the last year | Have you or someone else been injured as a result of your drinking?
Q10 | - No; - Yes, but not in the last year; - Yes, during the last year | Has a relative, friend, doctor, or other health worker been concerned about your drinking or suggested that you cut down?

Your score on the AUDIT is ____.

A score of eight points or less is considered nonalcoholic, while nine points and above indicates alcoholism.

Your score of ____ does not indicate a problem with alcoholism.

## Brief Situational Confidence Questionnaire (BSCQ)

Brief Situational Confidence Questionnaire (BSCQ)

Brief Situational Confidence Questionnaire (BSCQ)

Name: | ________________________________ | Date: | ________________________________
Listed below are eight types of situations in which some people experience an alcohol or drug problem. Imagine yourself as you are right now in each of the following types of situations. Indicate on the scale provided how confident you are right now that you will be able to resist drinking heavily or resist the urge to use your primary drug in each situation by placing an "X" along the line, from 0% "Not at all confident" to 100% "Totally confident" as in the example below.
I feel...
X
| _________________________________________
| 0% Not at all confident | 100% Totally confident
Right now I would be able to resist the urge to drink heavily or use my primary drug in situations involving...
1. | UNPLEASANT EMOTIONS (e.g., If I were depressed about things in general; if everything were going badly for me).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
2. | PHYSICAL DISCOMFORT (e.g., If I were to have trouble sleeping; if I felt jumpy and physically tense).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
3. | PLEASANT EMOTIONS (e.g., If something good happened and I felt like celebrating; if everything were going well).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
Right now I would be able to resist the urge to drink heavily or use my primary drug in situations involving...
4. | TESTING CONTROL OVER MY USE OF ALCOHOL OR DRUGS (e.g., If I were to start to believe that alcohol or drugs were no longer a problem for me; if I felt confident that I could handle drugs or several drinks).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
5. | URGES AND TEMPTATIONS (e.g., If I suddenly had an urge to drink or use drugs; if I were in a situation where I had often used drugs or drank heavily).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
6. | CONFLICT WITH OTHERS (e.g., If I had an argument with a friend; if I were not getting along well with others at work).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
7. | SOCIAL PRESSURE TO USE (e.g., If someone were to pressure me to "be a good sport" and drink or use drugs with him; if I were invited to someone's home and he offered me a drink or drugs).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident
8. | PLEASANT TIMES WITH OTHERS (e.g., If I wanted to celebrate with a friend; if I were enjoying myself at a party and wanted to feel even better).
I feel...
| _________________________________________
| 0% Not at all confident | 100% Totally confident

## Personal Feedback Report

Personal Feedback Report

Personal Feedback Report

Location: ____________________________________
Name: ________________________________________ | | | ID: __________
1. | YOUR DRINKING___________________________________________________
| Number of standard "drinks" per week: | | __________ drinks
| Your drinking relative to American adults (same sex): | | __________ percentile
2. | LEVEL OF INTOXICATION __________________________________________
| Estimated Blood Alcohol Concentration (BAC) peaks:
| in a typical week: | | __________ mg %
| on a heavier day of drinking: | | __________ mg %
3. | RISK FACTORS ___________________________________________________
| Tolerance Level:
| _____ Low (0-60) | _____ Medium (61-120) | _____ High (121-180) | _____ Very High (181 +)
| Other Drug Risk:
| _____ Low | _____ Medium | _____ High
| Family Risk: _____
| Low: 0-1 | Medium: 2-3 | High: 4-6 | Very High: 7 +
| MacAndrew Score: _______
| Normal Range: 0-23 | Medium Risk: 24-29 | High Risk: 30 +
| Age at Onset: _____ years
| Under 25 Higher Risk | 25-39 Medium Risk | 40 + Lower Risk
4. | NEGATIVE CONSEQUENCES _______________________________________
| Severity of Problems
| Low | Medium | High | Very High
| AUDIT
| 0-7 | 8-15 | 16-25 | 26-40
| Your Score: _______
| DRINC: Ever happened
| Low | Medium | High | Very High
| 55-60 | 61-75 | 76-90 | 91+
| Your Score: _______
| (Additional information on attached sheet.)
5. | BLOOD TESTS ____________________________________________________________
| SGOT (AST): __________ | | Normal range: 5-35
| GGTP (GGT): | | Normal range: 0-30 Low Normal 31-50 High Normal 51 + Elevated/Abnormal
| SGPT (ALT): __________ | | Normal range: 7-56
| Uric Acid: __________ | | Normal range: 2.6-5.6
| Bilirubin: __________ | | Normal range: 0.2-1.2
6. | NEUROPSYCHOLOGICAL TESTS ____________________________________
SV | Well Above Average 1 | Above Average 2 | Average 3 | Below Average 4 | Well Below Average 5
TMTA | 1 | 2 | 3 | 4 | 5
TMTB | 1 | 2 | 3 | 4 | 5
SYDM | 1 | 2 | 3 | 4 | 5
SHVA | 1 | 2 | 3 | 4 | 5
Therapist:___________________________________________________

## Understanding Your Personal Feedback Report

The Personal Feedback Report summarizes results from your pretreatment evaluation. Your therapist has explained these to you. This information is to help you understand the written report you have received and to remember what your therapist told you.

Your report consists of two sheets. The first sheet provides information from your pretreatment interviews. Attached to this is a second sheet summarizing your answers to a questionnaire, the Alcohol Use Inventory. The following information is presented section by section to help you understand what your results mean.

### 1. Your drinking

The first line in this section shows the number of drinks that you reported having in a typical drinking week. Because different alcohol beverages vary in their strength, we have converted your regular drinking pattern into standard "one drink" units. In this system, one drink is equal to

10 ounces of beer | (5 percent alcohol) or
4 ounces of table wine | (12 percent alcohol) or
2.5 ounces of fortified wine (sherry, port, etc.) | (20 percent alcohol) or
1.25 ounces of 80 proof liquor | (40 percent alcohol) or
1 ounce of 100 proof liquor | (50 percent alcohol)

All of these drinks contain the same amount of the same kind of alcohol: one-half ounce of pure ethyl alcohol.

ONE STANDARD DRINK IS:
Beer | 10 oz | Wine | 4 oz | 80 proof liquor | 1 oz | 100 proof liquor | 1 oz

This first piece of information, then, tells you how many of these standard drinks you have been consuming per week of drinking, according to what you reported in your interview. (If you have not been drinking for a period of time recently, this refers to your pattern of drinking before you stopped.)

To give you an idea of how this compares with the drinking of American adults in general, the second number in section 1 is a percentile figure. This tells you what percentage of U.S. men (if you are a man) or women (if you are a woman) drink less than you reported drinking in a typical week of drinking. If this number were 60, for example, it would mean that your drinking is higher than 60 percent of Americans of your sex (or that 40 percent drink as much as you reported, or more).

How much is too much? It depends on many factors. Current research indicates that people who average three or more standard drinks per day have much higher risk of health and social problems. For some people, however, even 1-2 drinks per day would be too many. Pregnant women, for example, are best advised to abstain from alcohol altogether, because even small amounts of regular drinking have been found to increase risk for the unborn child. Certain health problems (such as liver disease) make even moderate drinking unsafe. Some people find that they are unable to drink moderately, and having even one or two drinks leads to intoxication.

Your total number of drinks per week tells only part of the story. It is not healthy, for example, to have 12 drinks per week by saving them all up for Saturdays. Neither is it safe to have even a few drinks and then drive. This raises the important question of level of intoxication.

### 2. Level of intoxication

A second way of looking at your past drinking is to ask what level of intoxication you have been reaching. It is possible to estimate the amount of alcohol that would be circulating in your bloodstream, based on the pattern of drinking you reported. Blood alcohol concentration (BAC) is an important indication of the extent to which alcohol would be affecting your body and behavior. It is used by police and the courts, for example, to determine whether a driver is too impaired to operate a motor vehicle.

To understand better what BAC means, consider the list of common effects of different levels of intoxication.

Common Effects of Different Levels of Intoxication

20-60 mg %

The two figures shown in section 2 are computer-calculated estimates of your highest (peak) BAC level during a typical week of drinking and during one of your heaviest days of drinking.

It is important to realize that there is no known "safe" level of intoxication when driving or engaging in other potentially hazardous activities (such as swimming, boating, hunting, and operating tools or machinery). Blood alcohol levels as low as 40-60 mg % can decrease crucial abilities. Adding to the danger, drinkers typically do not realize that they are impaired. The only safe BAC when driving is zero. If you must drive after drinking, plan to allow enough time for all of the alcohol to be eliminated from your body before driving. The tables below can be helpful in determining how long it takes to eliminate alcohol completely:

Approximate hours from first drink to zero alcohol concentration levels for MEN

2

Approximate hours from first drink to zero alcohol concentration levels for WOMEN

3

### 3. Risk factors

It is clear that some people have a much higher risk of alcohol and other drug problems. This section provides you with some information about your own level of risk, based on your personal characteristics. "High risk" does not mean that one will definitely have serious problems with alcohol or other drugs. Neither does "low risk" mean that one will be free of such problems. High-risk people, however, have greater chances of developing serious problems.

#### Tolerance

Your peak BAC levels, given in section 2, are one reasonably good reflection of your level of tolerance for alcohol. If you are reaching BAC levels beyond the normal social drinking range (especially if you are not feeling some of the normal effects of lower BACs), it means that you have a higher tolerance for alcohol. This is partly hereditary and partly the result of changes in the body that occur with heavier drinking. Some people are proud of this tolerance--the ability "to hold your liquor"--and think it means they are not being harmed by alcohol. Actually, the opposite is true. Tolerance for alcohol may be a serious risk factor for alcohol problems. The person with a high tolerance for alcohol reaches high BAC levels, which can damage the brain and other organs of the body but has no built-in warning that it is happening. Tolerance is not a protection against being harmed by drinking; to the contrary, it makes damage more likely because of the false confidence that it encourages. It is a bit like a person who has no sense of pain. Pain is an important warning signal. People who feel no pain can seriously injure themselves without realizing it. It is the same with people who have a high tolerance for alcohol.

Many people believe that tolerance ("holding your liquor") means that a person gets rid of alcohol at a faster rate than others. Although people do differ in how quickly their bodies can clear alcohol, tolerance has more to do with actually being at a high blood alcohol level and not feeling it.

#### Other drug use

A person who uses other drugs besides alcohol runs several additional risks. Decreased use of one drug may simply result in the increased use of another. The effects of different drugs can multiply when they are taken together, with dangerous results. A tolerance to one drug can increase tolerance to another, and it is common for multiple drug users to become addicted to several drugs. The use of other drugs, then, increases your risk for serious problems. Based on the lifetime drug use that you reported during your interview, your risk in this regard was judged to be low, medium, or high.

#### Family risk

People who have a family history of alcohol or other drug problems among their blood relatives clearly are at higher risk themselves. The exact reason for this higher risk is unknown, but it appears that the risk is inherited to an important extent. People may inherit a higher tolerance for alcohol or a body that is particularly sensitive to alcohol in certain ways. In any event, a family history of alcohol problems increases personal risk.

#### Personality pattern

Although there is no single personality style associated with alcohol and drug problems, certain patterns are linked to higher risk. One questionnaire you completed--the MacAndrew Scale--measures this particular kind of risk. People who score higher on this scale as teenagers, for example, have been found to have higher risk for developing serious problems with alcohol in adulthood.

#### Age at onset

Recent research indicates that the younger a person is when drinking problems start, the greater the person's risk for developing serious consequences and dependence. Although serious problems can occur at any time of life, a younger beginning does represent a significant risk factor.

### 4. Negative consequences

From your pretreatment interview, two scores were calculated to reflect the current overall severity of your negative consequences from drinking.

#### AUDIT

The AUDIT is a scale devised by the World Health Organization to evaluate a person's problematic involvement with alcohol. Higher scores reflect recent problems related to drinking.

#### DRINC

Another way to look at risks and effects of drinking is to add up alcohol's negative effects throughout one's lifetime. Your score on this scale reflects the extent to which your drinking has had negative effects over the course of your life thus far. The higher your score, the more harm has resulted from your drinking.

### 5. Blood tests

Your pretreatment evaluation also included a blood sample. These particular blood tests were chosen because they have been shown in previous research to be negatively affected by heavy drinking. You should realize that normal results on these tests do not guarantee that you are in good health (for example, that your liver is functioning completely normally). An abnormal score on one or more of these tests, however, probably reflects unhealthy changes in your body resulting from excessive use of alcohol and/or other drugs.

Research indicates that modestly abnormal scores on the blood tests reported here will often show improvement and a return to normal range when harmful drinking and other drug use patterns are changed. The longer one continues drinking, however, the more difficult it is to reverse the physical damage.

These tests are directly related to how the liver is working. Your liver is extremely important to your health. It is involved in producing energy, and it filters and neutralizes impurities and poisons in your bloodstream. Alcohol damages the liver, and after a long period of heavy drinking, parts of the liver begin to die. This is the process of cirrhosis, but physical changes in the liver can be caused by drinking long before cirrhosis appears. As the liver becomes damaged, it begins to leak enzymes into the blood and is less efficient in doing its work. This can be reflected in abnormally elevated values on the tests reported in this section.

Elevated values on any of these tests should be taken seriously. They do not happen by chance and are very likely related to physical changes in the body caused by excessive drinking. Consult a physician who is knowledgeable about the effects of alcohol on the body.

### 6. Neuropsychological tests

Some of the earliest damaging effects of drinking may be seen in certain types of abilities that are affected by alcohol. Certain patterns of brain impairment have been shown to be especially related to heavy drinking. The brain is very vulnerable to alcohol, and over a long span of time, a substantial amount of damage can occur in a heavy drinker. (Brain impairment from the use of certain other drugs has also been shown.)

Such damage occurs gradually. In later stages, it can be seen in x-rays of the brain, which show actual shrinkage and other changes in shape and density. Long before this occurs, however, harmful changes in brain functioning can be measured by psychological tests, several of which you completed. Research indicates that such negative effects can often be reversed, sometimes completely, if the individual stops or reduces drinking.

The four tests included in section 6 have been found to be related to heavy drinking. For comparison purposes, we include one test (SV) that is not usually affected by drinking to give you an idea of where your scores might normally be expected to fall. People who are heavy drinkers tend to score more poorly (higher) on the four alcohol-sensitive tests (TMTA, TMTB, SYDM, and SHVA) than on SV.

A high score on any one scale is not necessarily reason for concern. There are many reasons why a single score might be elevated. A pattern of elevated scores, however, resembles the kinds of problems that emerge among excessive drinkers. Studies of individuals currently in treatment for alcohol problems consistently show impairment on these measures.

Alcohol's effects on the brain have sometimes been described as "premature aging." The abnormal changes in the brain of a heavy drinker do resemble normal changes that occur with advanced age. For this reason, your scores reflected above take into account your present age. Scores of 4 or 5 represent below-average performance relative to others in your age group.

### Summary

Your Personal Feedback Report summarizes a large amount of information that you provided during your pretreatment interviews. Sometimes this information can seem surprising or even discouraging. The best use of feedback like this is to consider it as you decide what, if anything, you will do about your drinking. Many of the kinds of problems covered in your Personal Feedback Report do improve when heavy drinking is stopped. What you do with this information is up to you. Your report is designed to give you a clear picture of where you are at present so that you can make good decisions about where you want to go from here.

Readiness To Change Questionnaire (Treatment Version) (RCQ-TV)

Readiness To Change Questionnaire (Treatment Version) (RCQ-TV)

The following questionnaire is designed to identify how you personally feel about your drinking right now. Please think about your current situation and drinking habits, even if you have given up drinking completely. Read each question below carefully, and then decide whether you agree or disagree with the statements. Please tick the answer of your choice to each question. If you have any problems, please ask the questionnaire administrator.
Your answers are completely private and confidential
Key: SD = Strongly Disagree D = Disagree U = Unsure A = Agree SA = Strongly Agree
| | SD | D | U | A | SA | For office use only
1. | There is no need for me to change my drinking habits. | _____ | _____ | _____ | _____ | _____ | PC
2. | I enjoy my drinking, but sometimes I drink too much. | _____ | _____ | _____ | _____ | _____ | C
3. | I have reached the stage where I should seriously think about giving up or drinking less alcohol. | _____ | _____ | _____ | _____ | _____ | PA
4. | I am trying to stop drinking or drink less than I used to. | _____ | _____ | _____ | _____ | _____ | A
5. | I was drinking too much at one time, but now I've managed to cut down (or stop) my drinking. | _____ | _____ | _____ | _____ | _____ | M
6. | It's a waste of time thinking about my drinking because I do not have a problem. | _____ | _____ | _____ | _____ | _____ | PC
7. | Sometimes I think I should quit or cut down on my drinking. | _____ | _____ | _____ | _____ | _____ | C
8. | I have decided to do something about my drinking. | _____ | _____ | _____ | _____ | _____ | PA
9. | I know that my drinking has caused problems, and I'm now trying to correct this. | _____ | _____ | _____ | _____ | _____ | A
10. | I have changed my drinking habits (either cut down or quit), and I'm trying to keep it that way. | _____ | _____ | _____ | _____ | _____ | M
11. | There is nothing seriously wrong with my drinking. | _____ | _____ | _____ | _____ | _____ | PC
12. | My drinking is a problem sometimes. | _____ | _____ | _____ | _____ | _____ | C
13. | I'm preparing to change my drinking habits (either cut down or give up completely). | _____ | _____ | _____ | _____ | _____ | PA
14. | Anyone can talk about wanting to do something about their drinking, but I am actually doing something about it. | _____ | _____ | _____ | _____ | _____ | A
15. | It is important for me to hold onto the changes I've made, now that I've cut down (or quit) drinking. | _____ | _____ | _____ | _____ | _____ | M
16. | I am a fairly normal drinker. | _____ | _____ | _____ | _____ | _____ | PC
17. | I am weighing up the advantages and disadvantages of my present drinking habits. | _____ | _____ | _____ | _____ | _____ | C
18. | I have made a plan to stop or cut down drinking, and I intend to put this plan into practice. | _____ | _____ | _____ | _____ | _____ | PA
19. | I am actually changing my drinking habits right now (either cutting down or quitting). | _____ | _____ | _____ | _____ | _____ | A
20. | I have already done something about my drinking (either cut down or stopped completely), and I'm trying to avoid slipping back. | _____ | _____ | _____ | _____ | _____ | M
21. | Giving up or drinking less alcohol would be pointless for me. | _____ | _____ | _____ | _____ | _____ | PC
22. | I'm uncertain whether or not I drink too much. | _____ | _____ | _____ | _____ | _____ | C
23. | I have a drinking problem, and I really want to do something about it. | _____ | _____ | _____ | _____ | _____ | PA
24. | I have started to carry out a plan to cut down or quit drinking. | _____ | _____ | _____ | _____ | _____ | A
25. | I am working hard to prevent having a relapse of my drinking problem. | _____ | _____ | _____ | _____ | _____ | M
26. | There is nothing I really need to change about my drinking. | _____ | _____ | _____ | _____ | _____ | PC
27. | Sometimes I wonder if my drinking is out of control. | _____ | _____ | _____ | _____ | _____ | C
28. | If I don't change my drinking soon, my problems will just get worse. | _____ | _____ | _____ | _____ | _____ | PA
29. | I am actively working on my drinking problem. | _____ | _____ | _____ | _____ | _____ | A
30. | I've succeeded in stopping or cutting down drinking. | _____ | _____ | _____ | _____ | _____ | M

Situational Confidence Questionnaire (SCQ-39)

Situational Confidence Questionnaire (SCQ-39)

Listed below are a number of situations or events in which some people experience a drinking problem. Imagine yourself as you are right now in each of these situations. Indicate on the scale provided how confident you are that you would be able to resist the urge to drink heavily in that situation. Circle 100 if you are 100 percent confident right now that you could resist the urge to drink heavily; 80 if you are 80 percent confident; 60 if you are 60 percent confident. If you are more unconfident than confident, circle 40 to indicate that you are only 40 percent confident that you could resist the urge to drink heavily; 20 for 20 percent confident; 0 if you have no confidence at all about that situation.
| | I would be able to resist the urge to drink heavily
| | not at all confident | | | | | very confident
1. | If I felt that I had let myself down | 0 | 20 | 40 | 60 | 80 | 100
2. | If there were fights at home | 0 | 20 | 40 | 60 | 80 | 100
3. | If I had trouble sleeping | 0 | 20 | 40 | 60 | 80 | 100
4. | If I had an argument with a friend | 0 | 20 | 40 | 60 | 80 | 100
5. | If other people didn't seem to like me | 0 | 20 | 40 | 60 | 80 | 100
6. | If I felt confident and relaxed | 0 | 20 | 40 | 60 | 80 | 100
7. | If I were out with friends and they stopped by the bar for a drink | 0 | 20 | 40 | 60 | 80 | 100
8. | If I were enjoying myself at a party and wanted to feel even better | 0 | 20 | 40 | 60 | 80 | 100
9. | If I remembered how good it tasted | 0 | 20 | 40 | 60 | 80 | 100
10. | If I convinced myself that I was a new person and could take a few drinks | 0 | 20 | 40 | 60 | 80 | 100
11. | If I were afraid that things weren't going to work out | 0 | 20 | 40 | 60 | 80 | 100
12. | If other people interfered with my plans | 0 | 20 | 40 | 60 | 80 | 100
13. | If I felt drowsy and wanted to stay alert | 0 | 20 | 40 | 60 | 80 | 100
14. | If there were problems with people at work | 0 | 20 | 40 | 60 | 80 | 100
15. | If I felt uneasy in the presence of someone | 0 | 20 | 40 | 60 | 80 | 100
16. | If everything were going well | 0 | 20 | 40 | 60 | 80 | 100
17. | If I were at a party and other people were drinking | 0 | 20 | 40 | 60 | 80 | 100
18. | If I wanted to celebrate with a friend | 0 | 20 | 40 | 60 | 80 | 100
19. | If I passed by a liquor store | 0 | 20 | 40 | 60 | 80 | 100
20. | If I wondered about my self-control over alcohol and felt like having a drink to try it out | 0 | 20 | 40 | 60 | 80 | 100
21. | If I were angry at the way things had turned out | 0 | 20 | 40 | 60 | 80 | 100
22. | If other people treated me unfairly | 0 | 20 | 40 | 60 | 80 | 100
23. | If I felt nauseous | 0 | 20 | 40 | 60 | 80 | 100
24. | If pressure built up at work because of the demands of my supervisor | 0 | 20 | 40 | 60 | 80 | 100
25. | If someone criticized me | 0 | 20 | 40 | 60 | 80 | 100
26. | If I felt satisfied with something I had done | 0 | 20 | 40 | 60 | 80 | 100
27. | If I were relaxed with a good friend and wanted to have a good time | 0 | 20 | 40 | 60 | 80 | 100
28. | If I were in a restaurant, and the people with me ordered drinks | 0 | 20 | 40 | 60 | 80 | 100
29. | If I unexpectedly found a bottle of my favorite booze | 0 | 20 | 40 | 60 | 80 | 100
30. | If I started to think that just one drink could cause no harm | 0 | 20 | 40 | 60 | 80 | 100
31. | If I felt confused about what I should do | 0 | 20 | 40 | 60 | 80 | 100
32. | If I felt under a lot of pressure from family members at home | 0 | 20 | 40 | 60 | 80 | 100
33. | If my stomach felt like it was tied in knots | 0 | 20 | 40 | 60 | 80 | 100
34. | If I were not getting along well with others at work | 0 | 20 | 40 | 60 | 80 | 100
35. | If other people around me made me tense | 0 | 20 | 40 | 60 | 80 | 100
36. | If I were out with friends "on the town" and wanted to increase my enjoyment | 0 | 20 | 40 | 60 | 80 | 100
37. | If I met a friend and he/she suggested that we have a drink together | 0 | 20 | 40 | 60 | 80 | 100
38. | If I suddenly had an urge to drink | 0 | 20 | 40 | 60 | 80 | 100
39. | If I wanted to prove to myself that I could take a few drinks without becoming drunk | 0 | 20 | 40 | 60 | 80 | 100

## Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

INSTRUCTIONS: Please read the following statements carefully. Each one describes a way that you might (or might not) feel about your drinking. For each statement, circle one number from 1 to 5, to indicate how much you agree or disagree with it right now. Please circle one and only one number for every statement.
| NO! Strongly Disagree | No Disagree | ? Undecided or Unsure | Yes Agree | YES! Strongly Agree
1. I really want to make changes in my drinking. | 1 | 2 | 3 | 4 | 5
2. Sometimes I wonder if I am an alcoholic. | 1 | 2 | 3 | 4 | 5
3. If I don't change my drinking soon, my problems are going to get worse. | 1 | 2 | 3 | 4 | 5
4. I have already started making some changes in my drinking. | 1 | 2 | 3 | 4 | 5
5. I was drinking too much at one time, but I've managed to change my drinking. | 1 | 2 | 3 | 4 | 5
6. Sometimes I wonder if my drinking is hurting other people. | 1 | 2 | 3 | 4 | 5
7. I am a problem drinker. | 1 | 2 | 3 | 4 | 5
8. I'm not just thinking about changing my drinking, I'm already doing something about it. | 1 | 2 | 3 | 4 | 5
9. I have already changed my drinking, and I am looking for ways to keep from slipping back to my old pattern. | 1 | 2 | 3 | 4 | 5
10. I have serious problems with drinking. | 1 | 2 | 3 | 4 | 5
11. Sometimes I wonder if I am in control of my drinking. | 1 | 2 | 3 | 4 | 5
12. My drinking is causing a lot of harm. | 1 | 2 | 3 | 4 | 5
13. I am actively doing things now to cut down or stop drinking. | 1 | 2 | 3 | 4 | 5
14. I want help to keep from going back to the drinking problems that I had before. | 1 | 2 | 3 | 4 | 5
15. I know that I have a drinking problem. | 1 | 2 | 3 | 4 | 5
16. There are times when I wonder if I drink too much. | 1 | 2 | 3 | 4 | 5
17. I am an alcoholic. | 1 | 2 | 3 | 4 | 5
18. I am working hard to change my drinking. | 1 | 2 | 3 | 4 | 5
19. I have made some changes in my drinking, and I want some help to keep from going back to the way I used to drink. | 1 | 2 | 3 | 4 | 5
For scoring and interpretation information of SOCRATES, see pp. 221-223.

### Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8D)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

INSTRUCTIONS: Please read the following statements carefully. Each one describes a way that you might (or might not) feel about your drug use. For each statement, circle one number from 1 to 5, to indicate how much you agree or disagree with it right now. Please circle one and only one number for every statement.
| NO! Strongly Disagree | No Disagree | ? Undecided or Unsure | Yes Agree | YES! Strongly Agree
1. I really want to make changes in my use of drugs. | 1 | 2 | 3 | 4 | 5
2. Sometimes I wonder if I am an addict. | 1 | 2 | 3 | 4 | 5
3. If I don't change my drug use soon, my problems are going to get worse. | 1 | 2 | 3 | 4 | 5
4. I have already started making some changes in my use of drugs. | 1 | 2 | 3 | 4 | 5
5. I was using drugs too much at one time, but I've managed to change that. | 1 | 2 | 3 | 4 | 5
6. Sometimes I wonder if my drug use is hurting other people. | 1 | 2 | 3 | 4 | 5
7. I have a drug problem. | 1 | 2 | 3 | 4 | 5
8. I'm not just thinking about changing my drug use, I'm already doing something about it. | 1 | 2 | 3 | 4 | 5
9. I have already changed my drug use, and I am looking for ways to keep from slipping back to my old pattern. | 1 | 2 | 3 | 4 | 5
10. I have serious problems with drugs. | 1 | 2 | 3 | 4 | 5
11. Sometimes I wonder if I am in control of my drug use. | 1 | 2 | 3 | 4 | 5
12. My drug use is causing a lot of harm. | 1 | 2 | 3 | 4 | 5
13. I am actively doing things now to cut down or stop my use of drugs. | 1 | 2 | 3 | 4 | 5
14. I want help to keep from going back to the drug problems that I had before. | 1 | 2 | 3 | 4 | 5
15. I know that I have a drug problem. | 1 | 2 | 3 | 4 | 5
16. There are times when I wonder if I use drugs too much. | 1 | 2 | 3 | 4 | 5
17.I am a drug addict. | 1 | 2 | 3 | 4 | 5
18. I am working hard to change my drug use. | 1 | 2 | 3 | 4 | 5
19. I have made some changes in my drug use, and I want some help to keep from going back to the way I used before. | 1 | 2 | 3 | 4 | 5

### SOCRATES Scoring Form (19-Item Version 8)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Transfer the client's answers from questionnaire (see note below):
Recognition | Ambivalence | Taking Steps
1 ________ | 2 ________ | 4 ________
3 ________ | 5 ________
| 6 ________
7 ________ | | 8 ________
| 9 ________
10 ________ | 11 ________
12 ________ | | 13 ________
| 14 ________
15 ________ | 16 ________
17 ________ | | 18 ________
| | 19 ________
Totals: Re: ________ | Am: ________ | Ts: ________

### SOCRATES Profile Sheet (19-Item Version 8A)

INSTRUCTIONS: From the SOCRATES Scoring Form (19-Item Version) transfer the total scale scores into the empty boxes at the bottom of the Profile Sheet. Then for each scale, CIRCLE the same value above it to determine the decile range.

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES 8A)

DECILE SCORES | Recognition | Ambivalence | Taking Steps
90 (Very High) | | 19-20 | 39-40
80 | | 18 | 37-38
70 (High) | 35 | 17 | 36
60 | 34 | 16 | 34-35
50 (Medium) | 32-33 | 15 | 33
40 | 31 | 14 | 31-32
30 (Low) | 29-30 | 12-13 | 30
20 | 27-28 | 9-11 | 26-29
10 (Very Low) | 7-26 | 4-8 | 8-25
RAW SCORES (from Scoring Sheet) | Re= | Am= | Ts=

These interpretive ranges are based on a sample of 1,726 adult men and women presenting for treatment of alcohol problems through Project MATCH. Note that individual scores are therefore being ranked as low, medium, or high relative to people already presenting for alcohol treatment.

### Guidelines for Interpretation of SOCRATES-8 Scores

Using the SOCRATES Profile Sheet, circle the client's raw score within each of the three scale columns. This provides information as to whether the client's scores are low, average, or high relative to people already seeking treatment for alcohol problems. The following are provided as general guidelines for interpretation of scores, but it is wise in an individual case also to examine individual item responses for additional information.

#### RECOGNITION

HIGH scorers directly acknowledge that they are having problems related to their drinking, tending to express a desire for change and to perceive that harm will continue if they do not change.

LOW scorers deny that alcohol is causing them serious problems, reject diagnostic labels such as "problem drinker" and "alcoholic," and do not express a desire for change.

#### AMBIVALENCE

HIGH scorers say that they sometimes wonder if they are in control of their drinking, are drinking too much, are hurting other people, and/or are alcoholic. Thus a high score reflects ambivalence or uncertainty. A high score here reflects some openness to reflection, as might be particularly expected in the contemplation stage of change.

LOW scorers say that they do not wonder whether they drink too much, are in control, are hurting others, or are alcoholic. Note that a person may score low on ambivalence either because he "knows" his drinking is causing problems (high Recognition), or because he "knows" that he does not have drinking problems (low Recognition). Thus a low Ambivalence score should be interpreted in relation to the Recognition score.

#### TAKING STEPS

HIGH scorers report that they are already doing things to make a positive change in their drinking and may have experienced some success in this regard. Change is under way, and they may want help to persist or to prevent backsliding. A high score on this scale has been found to be predictive of successful change.

LOW scorers report that they are not currently doing things to change their drinking and have not made such changes recently.

University of Rhode Island Change Assessment Scale (URICA)

University of Rhode Island Change Assessment Scale (URICA)

Each statement below describes how a person might feel when starting therapy or approaching problems in his life. Please indicate the extent to which you tend to agree or disagree with each statement. In each case, make your choice in terms of how you feel right now, not what you have felt in the past or would like to feel. For all the statements that refer to your "problem," answer in terms of problems related to your drinking (illegal drug use). The words "here" and "this place" refer to your treatment center. There are five possible responses to each of the items in the questionnaire: 1 = Strongly Disagree 2 = Disagree 3 = Undecided 4 = Agree 5 = Strongly Agree Circle the number that best describes how much you agree or disagree with each statement.
| | STRONGLY DISAGREE | DISAGREE | UNDECIDED | AGREE | STRONGLY AGREE
1. | As far as I'm concerned, I don't have any problems that need changing. | 1 | 2 | 3 | 4 | 5
2. | I think I might be ready for some self-improvement. | 1 | 2 | 3 | 4 | 5
3. | I am doing something about the problems that had been bothering me. | 1 | 2 | 3 | 4 | 5
4. | It might be worthwhile to work on my problem. | 1 | 2 | 3 | 4 | 5
5. | I'm not the problem one. It doesn't make much sense for me to consider changing. | 1 | 2 | 3 | 4 | 5
6. | It worries me that I might slip back on a problem I have already changed, so I am looking for help. | 1 | 2 | 3 | 4 | 5
7. | I am finally doing some work on my problem. | 1 | 2 | 3 | 4 | 5
8. | I've been thinking that I might want to change something about myself. | 1 | 2 | 3 | 4 | 5
9. | I have been successful in working on my problem, but I'm not sure I can keep up the effort on my own. | 1 | 2 | 3 | 4 | 5
10. | At times my problem is difficult, but I'm working on it. | 1 | 2 | 3 | 4 | 5
11. | Trying to change is pretty much a waste of time for me because the problem doesn't have to do with me. | 1 | 2 | 3 | 4 | 5
12. | I'm hoping that I will be able to understand myself better. | 1 | 2 | 3 | 4 | 5
13. | I guess I have faults, but there's nothing that I really need to change. | 1 | 2 | 3 | 4 | 5
14. | I am really working hard to change. | 1 | 2 | 3 | 4 | 5
15. | I have a problem, and I really think I should work on it. | 1 | 2 | 3 | 4 | 5
16. | I'm not following through with what I had already changed as well as I had hoped, and I want to prevent a relapse of the problem. | 1 | 2 | 3 | 4 | 5
17. | Even though I'm not always successful in changing, I am at least working on my problem. | 1 | 2 | 3 | 4 | 5
18. | I thought once I had resolved the problem I would be free of it, but sometimes I still find myself struggling with it. | 1 | 2 | 3 | 4 | 5
19. | I wish I had more ideas on how to solve my problem. | 1 | 2 | 3 | 4 | 5
20. | I have started working on my problem, but I would like help. | 1 | 2 | 3 | 4 | 5
21. | Maybe someone or something will be able to help me. | 1 | 2 | 3 | 4 | 5
22. | I may need a boost right now to help me maintain the changes I've already made. | 1 | 2 | 3 | 4 | 5
23. | I may be part of the problem, but I don't really think I am. | 1 | 2 | 3 | 4 | 5
24. | I hope that someone will have some good advice for me. | 1 | 2 | 3 | 4 | 5
25. | Anyone can talk about changing; I'm actually doing something about it. | 1 | 2 | 3 | 4 | 5
26. | All this talk about psychology is boring. Why can't people just forget about their problems? | 1 | 2 | 3 | 4 | 5
27. | I'm struggling to prevent myself from having a relapse of my problem. | 1 | 2 | 3 | 4 | 5
28. | It is frustrating, but I feel I might be having a recurrence of a problem I thought I had resolved. | 1 | 2 | 3 | 4 | 5
29. | I have worries, but so does the next guy. Why spend time thinking about them? | 1 | 2 | 3 | 4 | 5
30. | I am actively working on my problem. | 1 | 2 | 3 | 4 | 5
31. | I would rather cope with my faults than try to change them. | 1 | 2 | 3 | 4 | 5

## What I Want From Treatment

William R. Miller and Janice M. Brown

### Instructions

People have different ideas about what they want, need, and expect from treatment.

This questionnaire is designed to help you explain what you would like to have happen in your treatment. Many possibilities are listed. For each one, please indicate how much you would like for this to be part of your treatment.

You can do this by circling one number (0, 1, 2, or 3) for each item. This is what the numbers mean:

Instructions

0 | NO | means that you definitely do NOT want or need this from treatment.
1 | ? | means that you are UNSURE. MAYBE you want this from treatment.
2 | YES | means that you DO want or need this from treatment.
3 | YES! | means that you DEFINITELY want or need this from treatment.

### FOR EXAMPLE:

Consider item #1, which says, "I want to receive detoxification." If you definitely do NOT want or need to receive detoxification, you would circle 0. If you are UNSURE whether you want or need detoxification, you would circle 1. If you DO want detoxification, you would circle 2. If you DEFINITELY know that detoxification is an important goal for your treatment, you would circle 3.

If you have any questions about how to use this questionnaire, ask for assistance before you begin.

What I Want From Treatment

What I Want From Treatment

What I Want From Treatment
  DO YOU WANT THIS FROM TREATMENT? [image] | | NO 0 | Maybe 1 | Yes 2 | YES! 3
  1. | I want to receive detoxification, to ease my withdrawal from alcohol or other drugs. | 0 | 1 | 2 | 3
  2. | I want to find out for sure whether I have a problem with alcohol or other drugs. | 0 | 1 | 2 | 3
  3. | I want help to stop drinking alcohol completely. | 0 | 1 | 2 | 3
  4. | I want help to decrease my drinking. | 0 | 1 | 2 | 3
  5. | I want help to stop using drugs (other than alcohol). | 0 | 1 | 2 | 3
  6. | I want to stop using tobacco. | 0 | 1 | 2 | 3
  7. | I want to decrease my use of tobacco. | 0 | 1 | 2 | 3
  8. | I want help with an eating problem. | 0 | 1 | 2 | 3
  9. | I want help with a gambling problem. | 0 | 1 | 2 | 3
  10. | I want to take Antabuse (a medication to help me stop drinking). | 0 | 1 | 2 | 3
  11. | I want to take Trexan (a medication to help me stop using alcohol or heroin). | 0 | 1 | 2 | 3
  12. | I want to take methadone. | 0 | 1 | 2 | 3
  13. | I want to learn more about alcohol/drug problems. | 0 | 1 | 2 | 3
  14. | I want to learn some skills to keep from returning to alcohol or other drugs. | 0 | 1 | 2 | 3
  15. | I would like to learn more about 12-Step programs like Alcoholics Anonymous (AA) or Narcotics Anonymous (NA). | 0 | 1 | 2 | 3
  16. | I would like to talk about some personal problems. | 0 | 1 | 2 | 3
  1. | I need to fulfill a requirement of the courts. | 0 | 1 | 2 | 3
  17. | I would like help with problems in my marriage or close relationship. | 0 | 1 | 2 | 3
  18. | I want help with some health problems. | 0 | 1 | 2 | 3
  19. | I want help to decrease my stress and tension. | 0 | 1 | 2 | 3
  20. | I would like to improve my health by learning more about nutrition and exercise. | 0 | 1 | 2 | 3
  21. | I want help with depression or moodiness. | 0 | 1 | 2 | 3
  23. | I want to work on my spiritual growth. | 0 | 1 | 2 | 3
  24. | I want to learn how to solve problems in my life. | 0 | 1 | 2 | 3
  25. | I want help with angry feelings and how I express them. | 0 | 1 | 2 | 3
  26. | I want to have healthier relationships. | 0 | 1 | 2 | 3
  27. | I would like to discuss sexual problems. | 0 | 1 | 2 | 3
  28. | I want to learn how to express my feelings in a more healthy way. | 0 | 1 | 2 | 3
  29. | I want to learn how to relax better. | 0 | 1 | 2 | 3
  30. | I want help in overcoming boredom. | 0 | 1 | 2 | 3
  31. | I want help with feelings of loneliness. | 0 | 1 | 2 | 3
  32. | I want to discuss having been physically abused. | 0 | 1 | 2 | 3
  33. | I want help to prevent violence at home. | 0 | 1 | 2 | 3
  34. | I want to discuss having been sexually abused. | 0 | 1 | 2 | 3
  35. | I want to work on having better self-esteem. | 0 | 1 | 2 | 3
  36. | I want help with sleep problems. | 0 | 1 | 2 | 3
  37. | I want help with legal problems. | 0 | 1 | 2 | 3
  38. | I want advice about financial problems. | 0 | 1 | 2 | 3
  39. | I would like help in finding a place to live. | 0 | 1 | 2 | 3
  40. | I could use help in finding a job. | 0 | 1 | 2 | 3
  41. | Someone close to me has died or left, and I would like to talk about it. | 0 | 1 | 2 | 3
  42. | I have thoughts about suicide, and I would like to discuss this. | 0 | 1 | 2 | 3
  43. | I want help with personal fears and anxieties. | 0 | 1 | 2 | 3
  44. | I want help to be a better parent. | 0 | 1 | 2 | 3
  45. | I feel very confused and would like help with this. | 0 | 1 | 2 | 3
  46. | I would like information about or testing for HIV/AIDS. | 0 | 1 | 2 | 3
  47. | I want someone to listen to me. | 0 | 1 | 2 | 3
  48. | I want to learn to have fun without drugs or alcohol. | 0 | 1 | 2 | 3
  49. | I want someone to tell me what to do. | 0 | 1 | 2 | 3
  50. | I want help in setting goals and priorities in my life. | 0 | 1 | 2 | 3
  51. | I would like to learn how to manage my time better. | 0 | 1 | 2 | 3
  52. | I want help to receive SSI/disability payments. | 0 | 1 | 2 | 3
  53. | I want to find enjoyable ways to spend my free time. | 0 | 1 | 2 | 3
  54. | I want help in getting my child(ren) back. | 0 | 1 | 2 | 3
  55. | I would like to talk about my past. | 0 | 1 | 2 | 3
  56. | I need help in getting motivated to change. | 0 | 1 | 2 | 3
  57. | I would like to see a female counselor. | 0 | 1 | 2 | 3
  58. | I would like to see a male counselor. | 0 | 1 | 2 | 3
  59. | I would like to see the counselor I had before. | 0 | 1 | 2 | 3
  60. | I would like to see a doctor or nurse about medical problems. | 0 | 1 | 2 | 3
  61. | I want to receive medication. | 0 | 1 | 2 | 3
  62. | I would like my spouse or partner to be in treatment with me. | 0 | 1 | 2 | 3
  63. | I would like to have private, individual counseling. | 0 | 1 | 2 | 3
  64. | I would like to be in a group with people who are dealing with problems similar to my own. | 0 | 1 | 2 | 3
  65. | I need someone to care for my children while I am in treatment. | 0 | 1 | 2 | 3
  66. | I want my treatment to be short. | 0 | 1 | 2 | 3
  67. | I believe I will need to be in treatment for a long time. | 0 | 1 | 2 | 3

Is there anything else you would like from treatment? If so, please write on the back of this sheet.