# Consensus Panel

Chair
- William R. Miller, Ph.D.
- Regents Professor of Psychology and Psychiatry
- Director of Research
- Center on Alcoholism, Substance Abuse, and Addictions
- Department of Psychology
- University of New Mexico
- Albuquerque, New Mexico

Workgroup Leaders
- Edward Bernstein, M.D., F.A.C.E.P.
- Associate Professor and Academic Affairs Vice Chairman
- Boston University School of Medicine
- Boston, Massachusetts
- Suzanne M. Colby, Ph.D.
- Assistant Professor of Psychiatry and Human Behavior
- Center for Alcohol and Addiction Studies
- Brown University
- Providence, Rhode Island
- Carlo C. DiClemente, Ph.D.
- Department of Psychology
- University of Maryland, Baltimore County
- Baltimore, Maryland
- Robert J. Meyers, M.A.
- Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico
- Maxine L. Stitzer, Ph.D.
- Professor of Psychiatry and Behavioral Biology
- Johns Hopkins University School of Medicine
- Baltimore, Maryland
- Allen Zweben, D.S.W.
- Director and Associate Professor of Social Work
- Center for Addiction and Behavioral Health Research
- University of Wisconsin at Milwaukee
- Milwaukee, Wisconsin

Panelists
- Ray Daw
- Executive Director
- Northwest New Mexico Fighting Back, Inc.
- Gallup, New Mexico
- Jeffrey M. Georgi, M.Div., C.S.A.C., C.G.P.
- Program Coordinator
- Duke Alcoholism & Addictions Program
- Clinical Associate
- Department of Psychiatry and Behavioral Science
- Duke University Medical Center
- Durham, North Carolina
- Cheryl Grills, Ph.D.
- Department of Psychology
- Loyola Marymount University
- Los Angeles, California
- Rosalyn Harris-Offutt, B.S., C.R.N.A., L.P.C., A.D.S.
- UNA Psychological Associates
- Greensboro, North Carolina
- Don M. Hashimoto, Psy.D.
- Clinical Director
- Ohana Counseling Services, Inc.
- Hilo, Hawaii
- Dwight McCall, Ph.D.
- Evaluation Manager
- Substance Abuse Services
- Virginia Department of Mental Health, Mental Retardation and Substance Abuse Services
- Richmond, Virginia
- Jeanne Obert, M.F.C.C., M.S.M.
- Director of Clinical Services
- Matrix Center
- Los Angeles, California
- Carole Janis Otero, M.A., L.P.C.C.
- Director
- Albuquerque Metropolitan Central Intake
- Albuquerque, New Mexico
- Roger A. Roffman, D.S.W.
- Innovative Programs Research Group
- School of Social Work
- Seattle, Washington
- Linda C. Sobell, Ph.D.
- Professor
- NOVA Southeastern University
- Fort Lauderdale, Florida