# Appendix F—Field Reviewers

- Henrietta Robin Barnes, M.D.
- Assistant Professor of Medicine
- Cambridge Health Alliance
- Cambridge Family Health
- Harvard Medical School
- Cambridge, Massachusetts

- Jerome R. Barry, M.S., L.M.H.D., C.P.C., C.A.D.A.C.
- Director
- St. Francis Medical Center
- Grand Island, Nebraska

- Insoo Kim Berg, Ph.D., M.S.W.
- Director
- The Brief Family Therapy Center
- Brookfield, Wisconsin

- JudyAnn Bigby, M.D.
- Medical Director
- Community Health Services
- Brigham and Women's Hospital
- Boston, Massachusetts

- Susan B. Blacksher, M.S.W.
- Executive Director
- California Association of Addiction Recovery Resources
- Sacramento, California

- Patricia Bradford, L.I.S.W., L.M.F.T., C.T.S.
- Clinical Social Worker/Coordinator
- WJB Dunn Medical Center
- Department of Veterans Affairs
- Columbia, South Carolina

- Milton Earl Burglass, M.D.
- Professor and Theologian
- Addiction Medicine
- Neuropsychiatric, Family, and Legal Medicine
- Homestead, Florida

- Anthony J. Cellucci, Ph.D.
- Associate Professor of Psychology
- Director, Idaho State University Clinic
- Idaho State University
- Pocatello, Idaho

- Larry Halverson, M.D.
- Springfield, Missouri
- Thomas J. Harvey, M.S.W.
- Senior Vice President for Member Services
- The Alliance for Children and Famlies
- Milwaukee, Wisconsin

- James N. Heckler, M.S., M.B.A., C.A.S.A.C.
- Managed Care Liaison
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York

- Pablo Hernandez, M.D.
- Administrator
- Division of Behavioral Health
- Department of Health, State of Wyoming
- Cheyenne, Wyoming

- John Higgins-Biddle, Ph.D.
- Assistant Professor/Project Director
- Cutting Back™
- Department of Community Medicine and Health Care
- University of Connecticut Health Center
- Farmington, Connecticut

- Jeff A. Hoffman, Ph.D.
- President
- Danya International, Inc.
- Silver Spring, Maryland

- Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling (PIDARC)
- Washington, D.C.

- Vaughn J. Howland, M.S.W., M.A.C.
- Director
- The Intervention Center
- Kensington, Maryland

- Darin Kawazoe, M.A., C.S.A.C.
- Director
- Hawaii Drug Court Program
- Honolulu, Hawaii

- Carol L. Kuprevich, M.A.
- Training Administrator
- Division of Alcoholism, Drug Abuse, and Mental Health
- Delaware Health and Social Services
- New Castle, Delaware

- Linda Lantrip, D.O.
- Medical Director/Dual Diagnosis Psychiatrist
- Little Rock Community Mental Health Center
- Mid-ARK Substance Abuse Series
- Little Rock, Arkansas

- Bruce R. Lorenz, B.S., C.A.D.C., N.C.A.C. II
- Director
- Thresholds, Inc.
- Georgetown, Delaware

- Russell P. MacPherson, Ph.D., C.A.P., C.A.P.P.,
- C.C.P., D.A.C., D.V.C.
- President
- RPM Addiction Prevention Training
- Deland, Florida

- Douglas B. Marlowe, Ph.D., J.D.
- Senior Scientist
- Treatment Research Institute at the University of Pennsylvania
- Philadelphia, Pennsylvania

- Ruby H. Martinez, R.N., Ph.D., C.S.
- Assistant Professor
- Acute and Long Term Care School of Nursing
- University of Colorado Health Sciences Center
- Denver, Colorado

- Susan McCrane, Ph.D.
- Associate Professor
- School of Nursing
- University of Maryland
- Baltimore, Maryland

- Lisa A. Melchior, Ph.D.
- Vice President
- The Measurement Group
- Culver City, California

- Scott D. Miller, Ph.D.
- Co-Founder
- Brief Therapy Training Consortium
- Institute for the Study of Therapeutic Change
- Chicago, Illinois

- Thomas Nicholson, Ph.D, M.P.H., M.A.Ed.
- Professor
- Department of Public Health
- Western Kentucky University
- Bowling Green, Kentucky

- Michele A. Packard, Ph.D.
- Executive Director
- Training and Consulting
- SAGE Institute
- Boulder, Colorado

- Michael Pantalon, Ph.D.
- Assistant Professor of Psychology
- Substance Abuse Center
- Department of Psychiatry
- Yale University School of Medicine
- New Haven, Connecticut

- Gilbert R. Parks, M.D.
- Board of Directors
- National Medical Association
- Topeka, Kansas

- Joe R. Pereira, L.I.C.S.W., C.A.S.
- Clinician/Trainer
- Recovery Strategies
- Belmont, Massachusetts

- Anthony M. Rizzo, Ph.D.
- Clinical Psychologist/Coordinator
- Chemical Dependency Programs
- Division of Mental Health
- SCRIPPS Clinic
- San Diego, California

- Maurilia Rodriquez, Ph.D., R.N., C.D.E.
- Health and Medical Services
- Houston Independent School District
- Houston, Texas

- Robert J. Schneider, Ed.D.
- Psychologist
- Harvard Vanguard Medical Associates
- Braintree, Massachusetts

- Anne H. Skinstad, Psy.D.
- Assistant Professor
- Division of Counseling, Rehabilitation, and Student Development
- Iowa Addiction Technology Training Center
- University of Iowa
- Iowa City, Iowa

- Richard E. Steinberg, M.S.
- President/CEO
- WestCare Foundation
- Las Vegas, Nevada

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Michael J. Taleff, Ph.D., C.A.C., M.A.C.,
- N.C.A.C. II
- Assistant Professor and Coordinator
- Graduate Programs in Chemical Dependency Counselor Education
- Department of Counselor Education, Counseling Psychology, and Rehabilitation Services
- Pennsylvania State University
- University Park, Pennsylvania

- Anthony Tusler
- Coordinator
- High Tech Center
- Santa Rosa Junior College
- Santa Rosa, California

- Nola C. Veazie, Ph.D., L.P.C., C.A.D.A.C.
- Superintendent
- Medical Services Department
- United States Air Force
- Santa Maria, California

- Robert Walker, M.S.W., L.C.S.W., B.C.D.
- Assistant Professor
- Center on Drug and Alcohol Research
- University of Kentucky
- Lexington, Kentucky

- Michael F. Weaver, M.D.
- Assistant Professor of Internal Medicine and Psychiatry
- Division of Substance Abuse Medicine
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia

- Ken C. Winters, Ph.D.
- Associate Professor
- Department of Psychiatry
- University of Minnesota
- Minneapolis, Minnesota

- David K. Yamakawa, Jr.
- Attorney at Law
- San Francisco, California