# Appendix E—Resource Panel

- Gregory Barranco
- Assistant Vice President
- Government Relations
- National Council for Community Behavioral Healthcare
- Rockville, Maryland

- Peggy Clark, M.S.W., M.P.A.
- Behavioral Health/Medicaid Managed Care
- Health Care Financing Administration
- Baltimore, Maryland

- Peter J. Cohen, M.D., J.D.
- Associate Professor of Law
- Georgetown University Law Center
- Washington, D.C.

- N. Ross Deck
- Deputy Director
- Office of Programs, Budget, Research, and Evaluation
- Office of National Drug Control Policy
- Washington, D.C.

- Col. Kenneth J. Hoffman, M.D., M.P.H., M.C.F.S.
- Drug and Alcohol Consultant
- Headquarters, 18th Medical Command
- Office of Army Surgeon General
- Yong San, Seoul, Korea

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Michael F. Weaver, M.D.
- Assistant Professor of Internal Medicine and Psychiatry
- Division of Substance Abuse Medicine
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia