# Appendix D—Health Promotion Workbook

Reprinted with permission from Barry, K.L., and Blow, F.C., 1998.

## Part 1: Summary of Health Habits

Let's review some of the information about your health, behavior, and health habits that we discussed in the clinic.

### Exercise

Exercise

Days per week you participated in vigorous activity | - none; - seldom; - 1-2 days per week; - 3-5 days per week; - 6-7 days per week
Minutes of exercise per day | - not applicable; - fewer than 15 minutes; - 15-30 minutes; - more than 30 minutes

### Nutrition

Nutrition

Weight change in last 6 months | - no change in weight; - gained more than 10 pounds; - lost more than 10 pounds; - don't know

### Tobacco Use

Tobacco Use

Tobacco used in last 6 months | - no; - yes; If yes, which ones?; - cigarettes; - chewing tobacco; - pipe
Average cigarettes smoked per day in last 6 months | - not applicable; - 1-9; - 10-19; - 20-29; - 30+

### Alcohol Use

Alcohol Use

Drinking days per week | - 1-2 days per week; - 3-4 days per week; - 5-6 days per week; - 7 days per week
Drinks per day | - 1-2 drinks; - 3-4 drinks; - 5-6 drinks; - 7 or more
Binge drinking within last month (5 or more drinks per occasion for women; 6 or more drinks per occasion for men) | - none; - 1-2 binges; - 3-5 binges; - 6-7 binges; - 8 or more
Are there any of these health behaviors (exercise, nutrition, tobacco use, alcohol use) with which you would like some help? | - no; - yes; If yes, which ones?; - exercise; - nutrition; - tobacco use; - alcohol use

## Part 2: Types of Drinkers in the U.S. Population

It is helpful to think about the amount of alcohol consumed by adults in the United States and by you. There are different types of drinkers among the adult population, and these types can be explained by different patterns of alcohol consumption. These include:

Part 2: Types of Drinkers in the U.S. Population

Types | Patterns of Alcohol Consumption
Abstainers and light drinkers | - Drink no alcohol or fewer than 3 drinks per month; - Alcohol use does not affect health or result in negative consequences; - Pregnant and breastfeeding women are advised to drink NO alcohol
Moderate drinkers | - Drink 3 or fewer times per week; - Drink 1-3 standard drinks per occasion; - Alcohol use does not affect health or result in negative consequences; - At times moderate drinkers consume NO alcohol, such as before driving, while operating machinery, while pregnant, etc.
At-risk drinkers | - Drink over 12 (women) and 15 (men) standard drinks per week; - At risk for negative health and social consequences
Alcoholics | - Heavy drinking has led to physical need for alcohol and to other problems

[image]

## Part 3: Consequences of Heavy Drinking

Drinking alcohol can affect your physical health, emotional and social well-being, and your relationships with others. The following are some of the positive effects that people sometimes describe as a result of drinking alcohol.

- Temporary high
- Forget one's problems
- Enjoy the taste
- Social ease
- Relaxation
- Sense of confidence and daring
- Temporarily reduced stress levels
- Avoid uncomfortable feelings
- Ease in speaking one's mind

The following are some of the negative consequences that may result from drinking.

- Difficulty coping with stressful situations
- Depression
- Blackouts
- Problems at work or school
- Liver problems
- Sexual performance problems
- Sleep problems
- Arrests for driving under the influence of alcohol
- Sexually transmitted diseases
- Car crashes
- High blood pressure
- Accidents/injuries
- Relationship problems
- Increased risk of sexual assault
- Financial problems

## Part 4: Reasons To Quit or Cut Down on Your Drinking

The purpose of this step is to think about the best reason for you to quit or cut down on your drinking. The reasons will be different for different people.

The following list identifies some of the reasons why people decide to cut down or quit drinking. Check each box by the three most important reasons why YOU want to quit or cut down on your drinking. Perhaps you can think of other reasons that are not on this list.

- To consume fewer empty calories (alcoholic drinks contain many calories)
- To sleep better
- To live longer--probably between 5 and 10 years longer
- To look younger
- To be less likely to die of heart disease or cancer
- To save lots of money
- To be happier
- To reduce the possibility that I will die of liver disease
- To reduce the possibility that I will die in a car crash
- To achieve more in my life
- To do better at my job
- To be a better father/mother to my children
- Other: ____________________________

Write down the three most important reasons you chose to cut down or quit drinking.

1. _______________________________________________________________
2. _______________________________________________________________
3. _______________________________________________________________

Think about the consequences of continuing to drink heavily. Now think about how your life might improve if you change your drinking habits by cutting down or quitting. What improvements do you anticipate?

Physical health:

Mental health:

Family:

Other relationships:

Work/school:

Financial:

Legal:

## Part 5: Drinking Agreement

The purpose of this step is to decide on a drinking limit for yourself for a particular period of time. Negotiate with your health care provider so you can both agree on a reasonable goal. A reasonable goal for some people is abstinence--not drinking any alcohol.

As you develop this agreement, answer the following questions:

- How many standard drinks (see below)?
- How frequently?
- For what period of time?

Part 5: Drinking Agreement

DRINKING AGREEMENT

Date: ________________________ Patient signature: ______________________________________________

Physician signature: ____________________________________________

The drinks shown below in normal measure contain roughly the same amount of pure alcohol. You can think of each one as a standard drink. [image]

### Drinking Diary Card

One way to keep track of how much you drink is the use of drinking diary cards. One card is used for each week. Every day record the number of drinks you have. At the end of the week add up the total number of drinks you had during the week.

Drinking Diary Card

Diary Card
KEEP TRACK OF WHAT YOU DRINK OVER THE NEXT 7 DAYS
STARTING DATE _______________
  Day | Beer | Wine | Liquor | Number
  Sunday
  Monday
  Tuesday
  Wednesday
  Thursday
  Friday
  Saturday
  | | | WEEK'S TOTAL:

## Part 6: Handling Risky Situations

Your desire to drink may change according to your mood, the people you are with, and the availability of alcohol. Think about your last periods of drinking.

Here are examples of risky situations. The following list may help you remember situations that can result in at-risk drinking.

- Parties
- Sleeplessness
- Anger
- Boredom
- Family
- Watching television
- Tension
- Friends
- Other people drinking
- Feeling lonely
- Criticism
- Certain places
- Feelings of failure
- Dinner parties
- After work
- Frustration
- Children
- Weekends
- Use of tobacco
- TV or magazine Ads
- Arguments

What are some situations that make you want to drink at a risky level? Please write them down.

1. ___________________________________________________________________________
2. ___________________________________________________________________________

### Ways To Cope With Risky Situations

It is important to figure out how you can make sure you will not go over drinking limits when you are tempted. Here are examples:

- Telephone a friend
- Go for a walk
- Call on a neighbor
- Watch a movie
- Read a book
- Participate in a sport

Some of these ideas may not work for you, but other methods of dealing with risky situations may work. Identify ways in which you could cope with the specific risky situations you listed above.

1. For the first risky situation or feeling, write down different ways of coping.

________________________________________________________________________

________________________________________________________________________

2. For the second risky situation or feeling, write down different ways of coping.

________________________________________________________________________

________________________________________________________________________

Think about other situations and ways in which you could cope without using alcohol.

### Visit Summary

We have covered a great deal of information today. Changing one's behavior, especially drinking patterns, can be a difficult challenge. The following pointers may help you stick with your new behavior and maintain the drinking limit agreement, especially during the first few weeks when it is most difficult.

- Remember that you are changing a habit and that it can be hard work. It becomes easier with time.
- Remember your drinking limit goal: __________________________________
- Read this workbook frequently.
- Every time you are tempted to drink above limits and are able to resist, congratulate yourself because you are breaking an old habit.
- Whenever you feel very uncomfortable, tell yourself that the feeling will pass.
- At the end of each week, think about how many days you have been abstinent (have consumed no alcohol) or have been a light or moderate drinker.
- Some people have days during which they drink too much. If that happens to you, DON'T GIVE UP. Just start again the next day.