# Appendix B—Information and Training Resources

## General Brief Therapy

### American Psychological Association (APA)--Division 29: Psychotherapy

Division of Psychotherapy P.O. Box 638 Niwot, CO 80544-0638 Phone: (303) 652-9154 Fax: (303) 652-2723 Web site: http://www.cwru.edu/affil/div29/ div29.htm E-mail: lpete@indra.com

APA, headquarted in Washington, DC, is the world's largest association of psychologists. APA's membership includes more than 159,000 researchers, educators, clinicians, consultants, and students. Through its divisions in 50 subfields of psychology and affiliations with 59 State, territorial, and Canadian provincial associations, APA works to advance psychology as a science, as a profession, and as a means of promoting human welfare.

Division 29 promotes education, research, high standards of practice, and the exchange of information among psychologists interested in psychotherapy.

## Cognitive-Behavioral Therapy

### Aaron T. Beck Institute for Cognitive Studies

Edmund F. O'Reilly, Ph.D. Founders Hall, Room 319 Assumption College 500 Salisbury Street P.O. Box 15005 Worcester, MA 01615-0005 Phone: (508) 767-7000, x 7554 Web site: http://www.assumption.edu/ E-mail: eoreill@eve.assumption.edu

The Aaron T. Beck Institute for Cognitive Studies provides information that highlights the contributions of cognitive factors to the resolution of problems in living. The Institute hosts annual speakers and conferences that address research and therapeutic development in cognitive therapy as well as ethical and moral issues. It also sponsors education and training projects in cognitive therapeutic skills to students and to postgraduate professionals.

### The Albert Ellis Institute

45 East 65th Street New York, NY 10021 Phone: (800) 323-4738 Web site: http://www.rebt.org/ E-mail: info@REBT.org

The Albert Ellis Institute, formerly known as the Institute for Rational-Emotive Therapy, is a not-for-profit educational organization founded in 1968. Rational Emotive Behavior Therapy (REBT) is a humanistic, action-oriented approach to emotional growth, first articulated by Dr. Albert Ellis in 1955, which emphasizes individuals' capacity for creating their emotions; the ability to change and overcome the past by focusing on the present; and the power to choose and implement satisfying alternatives to current behavior patterns. An estimated 8,000 mental health professionals participate in Institute training programs and workshops each year.

### The Association for Advancement Of Behavior Therapy (AABT)

305 Seventh Avenue - 16th Floor New York, NY 10001-6008 Phone: (212) 647-1890 Fax: (212) 647-1865 Web site: http://server.psyc.vt.edu/aabt/ E-mail: mebrown@aabt.org

AABT is a not-for-profit membership organization of over 4,500 mental health professionals and students. Founded in 1966, AABT serves as a centralized resource and network for all facets of behavior therapy and cognitive-behavior therapy. It promotes these therapies through its journals, newsletters, annual conventions, Web site, and other educational publications and programs. It also provides opportunities for professional growth and offers information and referral services to the general public, the media, third-party payors, and governmental and nongovernmental agencies.

### National Association of Cognitive-Behavioral Therapists (NACBT)

P.O. Box 2195 Weirton, WV 26062 Phone: (800) 853-1135 Fax: (304) 723-3982 Web site: http://www.nacbt.org/ E-mail: nacbt@nacbt.org

NACBT provides information on Rational Emotive Behavior Therapy (Albert Ellis), Rational Behavior Therapy (Maxie Maultsby), Cognitive Therapy (Aaron T. Beck), Rational Living Therapy (Aldo Pucci), and other cognitive-behavioral approaches. NACBT is dedicated to promoting the teaching and practice of cognitive-behavioral therapy and to supporting cognitive-behavioral therapists. NACBT offers cognitive-behavioral workshops, seminars, conferences, and home study certification programs.

## Strategic/Interactional Therapies

### Brief Family Therapy Center (BFTC)

P. O. Box 13736 Milwaukee, WI 53213-0736 Phone: (414) 302-0650 Fax: (414) 302-0753 Web site: http://www.brief-therapy.org E-mail: briefftc@aol.com

A not-for-profit research and training center founded in 1978, BFTC has pioneered effective brief therapy methods. The model developed at the center has come to be known as Solution-Focused Brief Therapy. This model has been used successfully for more than a decade in a variety of settings including child protection agencies, community mental health clinics, private practices, sexual abuse programs, substance abuse treatment, family-based services, and schools.

### The Milton H. Erickson Foundation, Inc.

3606 North 24th Street Phoenix, AZ 85016 Phone: (602) 956-6196 Fax: (602) 956-0519 Web site: http://erickson-foundation.org E-mail: office@erickson-foundation.org

The Milton H. Erickson Foundation, Inc., is dedicated to promoting and advancing the contributions made to the health sciences by the late Milton H. Erickson, M.D., through training mental health professionals worldwide. More than 60 Milton H. Erickson Institutes and Societies in the United States and abroad have applied to the Foundation for permission to use Dr. Erickson's name in the titles of their organizations. These institutes provide clinical services and professional training in major cities around the world.

### Institute for the Study of Therapeutic Change (ISTC)

P.O.B. 578264 Chicago, IL 60657-8264 Phone: (773) 404-5130 Fax: (773) 404-1840 Web site: http://www.talkingcure.com/ E-mail: scottdmiller@talkingcure.com

ISTC is a research, training, and consultation group dedicated to understanding and promoting human change, growth, and potential. ISTC studies how change occurs naturally, spontaneously, and on an everyday basis and then helps people and organizations apply that knowledge in solving problems.

### Mental Research Institute

555 Middlefield Road Palo Alto, CA 94301 Phone: (650) 321-3055 Fax: (650) 321-3785 Web site: http://www.mri.org E-mail: mri@mri.org

Since 1959, the Mental Research Institute of Palo Alto, California, has been a source of new ideas in the area of interactional/systemic studies, psychotherapy, and family therapy. It offers a variety of workshops and trainings related to brief therapy, narrative therapy, and strategic/interactional therapies.

## Humanistic and Existential Therapies

### State University of West Georgia

Department of Psychology 1600 Maple Street Carrollton, GA 30118 Phone: (770) 836-6510 Fax: (770) 836-6717 Web site: http://www.westga.edu/~psydept/index.html E-mail: meast@westga.edu

The State University of West Georgia Psychology Department is one of the only departments in the country whose theoretical roots are in the humanistic psychology and transpersonal psychology traditions. They offer courses that explore humanistic and transpersonal concerns in psychological theory and therapy.

### American Psychological Association (APA)--Division 32: Humanistic Psychology

Will Wadlington, Ph.D. Center for Counseling & Psychological Services 221 Ritenour University Park, PA 16802 Phone: (814) 863-0395 Fax: (814) 863-9610 Web site: http://www.apa.org/about/division/ div32.html E-mail: wlw3@psu.edu

Division 32 of the APA (see above), whose foundations include philosophical humanism, existentialism, and phenomenology, seeks to contribute to psychotherapy, education, theory/philosophy, research, organization and management, and social responsibility and change.

### Association for Humanistic Psychology (AHP)

45 Franklin Street #315 San Francisco, CA 94102 Phone: (415) 864-8850 Fax: (415) 864-8853 Web site: http://www.ahpweb.org/ E-mail: ahpoffice@aol.com

AHP was formed in 1962 by Abraham Maslow, Carl Rogers, Charlotte Buhler, Rollo May, Virginia Satir, and other founders of the personal growth movement. AHP is a forum for sharing ideas and inspiring community through a full calendar of conferences and events. Members also connect and pursue common interests through self-generated communities and projects called "Energy Centers," which offer personal and professional support and carry out activities and projects on specific issues.

### Institute of Transpersonal Psychology (ITP)

744 San Antonio Road Palo Alto, CA 94303 Phone: (650) 493-4430 Fax: (650) 493-6835 Web site: http://www.itp.edu/ E-mail: itpinfo@itp.edu

ITP is a private, nonsectarian graduate school accredited by the Western Association of Schools and Colleges. For more than 20 years, the Institute has remained at the forefront of psychological research and education, probing the mind-body-spirit connection. The Institute provides dynamic online/distance-learning opportunities using the personal mentor system, as well as an evening master's program for working adults.

### Saybrook Graduate School and Research Center

450 Pacific, 3rd Floor San Francisco, CA 94133-4640 Phone: (800) 825-4480 Fax: (415) 433-9271 Web site: http://www.saybrook.edu E-mail: saybrook@saybrook.edu.

The Saybrook Graduate School and Research Center provides master's and doctoral programs, research, and communication in humanistic psychology and human science, focused on understanding and enhancing the human experience.

## Psychodynamic Therapy

### American Psychoanalytic Association (APSA)

309 East 49th Street New York, NY 10017 Phone: (212) 752-0450 Fax: (212) 593-0571 Web site: http://apsa.org E-mail: central.office@apsa.org

APSA is a professional organization of psychoanalysts throughout the United States. The association comprises Affiliate Societies and Training Institutes in many cities (listed on their Web site at http://apsa.org/organiz/ society.htm) and has about 3,000 individual members. APSA is a Regional Association of the International Psychoanalytical Association.

### Alfred Adler Institute of San Francisco

7 Cameo Way San Francisco, CA 94131 Phone: (415) 282-1661 Web site: http://ourworld.compuserve.com/ homepages/hstein/homepage.htm E-mail: HTStein@worldnet.att.net

The Alfred Adler Institute provides distance training, study-analysis, and case consultation to mental health professionals and students throughout the world via telephone, E-mail, and the Institute's Web site documents. A unique mentor-based service offers self-paced programs through customized training, home study of audio-taped seminars, weekly discussions, and case consultations by telephone.

### The C.G. Jung Institutes

The Inter-Regional Society of Jungian Analysts Wilma H. Spice, Ph.D. 4135 Brownsville Road Pittsburgh, PA 15227 Phone: (412) 882-7010 Web site: http://www.cgjung.com/irsja.html E-mail: wspice@ccac.edu

There are a number of independent C.G. Jung Institutes in the United States, all of whom are members of the International Association for Analytical Psychology. In addition to the one listed above, other institutes exist in Washington, D.C., Philadelphia, San Francisco, Los Angeles, Chicago, Dallas, Boston, Santa Fe, New York, Seattle, and Eugene, Oregon. All of these institutes offer training programs, lectures, and workshops. (Contact information for the other Institutes can be found at: http://boulder.earthnet.net/cgjung/)

## Family Therapy

### American Association for Marriage And Family Therapy (AAMFT)

1133 15th Street, NW, Suite 300 Washington, DC 20005-2710 Phone: (202) 452-0109 Fax: (202) 223-2329 Web site: http://www.aamft.org/ E-mail: Central@aamft.org

AAMFT is the professional association for the field of marriage and family therapy, representing the professional interests of more than 23,000 marriage and family therapists throughout the United States, Canada, and abroad. The association facilitates research, theory development, and education. AAMFT hosts an annual national training conference each fall as well as a week-long series of continuing education workshops in the summer.

## Group Therapy

### American Psychological Association (APA)--Division 49: Group Psychology and Group Psychotherapy

Alan M. Orenstein, Ph.D. 9712 DePaul Drive Bethesda, MD 20817 Phone: (202) 373-7083 Web site: http://www.pitt.edu/~cslewis/GP2/ Hello.html E-mail: alano@erols.com

Division 49 of the APA (see above) provides a forum for psychologists interested in research, teaching, and practice in group psychology and group psychotherapy. Current projects include developing national guidelines for doctoral and postdoctoral training in group psychotherapy.

### Association for Specialists in Group Work (ASGW)

Jeremiah Donigian, President Department of Counselor Education SUNY College at Brockport Brockport, NY 14420 Phone: (800) 347-6647 Web site: http://www.colstate.edu/coe/asgw/ E-mail: jdonigia@po.brockport.edu

ASGW was founded to promote quality in group work training, practice, and research, both nationally and internationally. A division of the American Counseling Association (ACA), ASGW numbers among its members more than 5,800 group workers and group work educators. The ASGW Web site provides a resource base for teachers, students, and practitioners of group work and includes both organizational information and professional resources.