# Appendix A --Bibliography

Abbott, P.J.; Weller, S.B.; Delaney, H.D.; and Moore, B.A. Community reinforcement approach in the treatment of opiate addicts. American Journal of Drug and Alcohol Abuse. 1998;24(1):17-30. [pmid: 9513627].
Ablon, J. The significance of cultural patterning for the "alcoholic family.". Family Process. 1980;19(2):127-144. [pmid: 7409092].
Abrams, D.B., and Niaura, R.S. 1987.
Abramson, L.Y.; Seligman, M.E.; and Teasdale, J.D. Learned helplessness in humans: Critique and reformulation. Journal of Abnormal Psychology. 1978;87(1):49-74. [pmid: 649856].
Ackerman, R. 1986.
Ackerman, R. Motto for ACOAs: Let go and grow. Recovery Section. Alcoholism and Addiction. 1987;7(5):R10.
Aktan, G.B.; Kumpfer, K.L.; and Turner, C.W. Effectiveness of a family skills training program for substance abuse prevention with inner city African-American families. Substance Use and Misuse. 1996;31(2):157-175. [pmid: 8834005].
Al-Anon Family Groups, Inc. 1984.
Allen, J.P., and Columbus, M. 1995.
Alonso, A., and Rutan, J.S. Women in group therapy. International Journal of Group Psychotherapy. 1979;29(4):481-491. [pmid: 511405].
American Psychiatric Association. 1980.
American Psychiatric Association. 1994.
American Society of Addiction Medicine (ASAM).Principles of Addiction Medicine.1994
American Society of Addiction Medicine (ASAM).ASAM, 1996.
Amodeo, M. Treating the late life alcoholic: Guidelines for working through denial integrating individual, family, and group approaches. Journal of Geriatric Psychiatry. 1990;23(2):91-105. [pmid: 2290018].
Anderson, P., and Scott, E. The effect of general practitioners' advice to heavy drinking men. British Journal of Addiction. 1992;87(6):891-900. [pmid: 1525531].
Anker, A.L., and Crowley, T.J. 1982.
Annis, H.M., and Davis, C.S. 1988.
Annis, H.M., and Davis, C.S. 1988.
Annis, H.M., and Davis, C.S. 1989.
Annis, H.M., and Davis, C.S. Relapse prevention training: A cognitive-behavioral approach based on self-efficacy theory. Journal of Chemical Dependency Treatment. 1989;2(2):81-103.
Annis, H.M., and Davis, C.S. Relapse prevention. Alcohol Health & Research World. 1991;15(3):204-212.
Azrin, N.H. Improvements in the community-reinforcement approach to alcoholism. Behaviour Research and Therapy. 1976;14(5):339-348. [pmid: 971207].
Babor, T.F. 1991.
Babor, T.F. Avoiding the horrid and beastly sin of drunkenness: Does dissuasion make a difference?. Journal of Consulting and Clinical Psychology. 1994;62(6):1127-1140. [pmid: 7860811].
Babor, T.F., and Grant, M., eds. 1991.
Babor, T.F.; Grant, M.; Acuda, W.; Burns, F.H.; Campillo, C.; Del Boca, F.K.; Hodgson, R.; Ivanets, N.N.; Lukomskya, M.; Machona, M.; Rollnick, S.; Resnick, R.; Saunders, J.B.; Skutle, A.; Connor, K.; Ernberg, G.; Kranzler, H.; Lauerman, R.; and McRee, B. A randomized clinical trial of brief interventions in primary health care: Summary of a WHO project. Addiction. 1994;89(6):657-660. [pmid: 8069168].
Babor, T.F.; Ritson, E.B.; and Hodgson, R.J. Alcohol-related problems in the primary health care setting: A review of early intervention strategies. British Journal of Addiction. 1986;81:23-46.
Baker, H.S. 1991.
Bale, R. 1993.
Bandura, A. Self-efficacy: Toward a unifying theory of behavioral change. Psychological Review. 1977;84(2):191-215. [pmid: 847061].
Bandura, A. 1986.
Bandura, A. 1994.
Barber, J.P., and Crits-Christoph, P. 1991.
Barber, J.P.; Luborsky, L.; Crits-Christoph, P.; Thase, M.E.; Weiss, R.; Frank, A.; Onken, L.; and Gallop, R. Therapeutic alliance as a predictor of outcome in treatment of cocaine dependence. Psychotherapy Research. 1999;9:54-73.
Barry, K.L. 1997.
Barry, K.L., and Blow, F.C. 1998.
Barth, R.P.; Ramler, M.; and Pietrzak, J. 1993.
Bauer, G.P., and Kobos, J.C. 1987.
Beattie, M. 1987.
Beck, A.T. 1976.
Beck, A.T., and Freeman, A. 1990.
Beck, A.T., and Wright, F.D. 1992.
Beck, A.T.; Wright, F.D.; Newman L.; and Liese, B. 1993.
Beck, J.S. 1995.
Beck, J.S., and Liese, B.S. 1998.
Bekir, P.; McLellan, T.; Childress, A.R.; and Gariti, P. Role reversals in families of substance misusers: A transgenerational phenomenon. International Journal of the Addictions. 1993;28(7):613-630. [pmid: 8500924].
Bepko, C. 1985.
Berg, I.K. 1995.
Berg, I.K., and Miller, S.D. 1992.
Berg, I.K., and Reuss, N. Solution-focused brief therapy: Treating substance abuse. Current Thinking and Research in Brief Therapy. 1998;2:57-83.
Bernstein, S., ed. 1965.
Bien, T.H.; Miller, W.R.; and Tonigan, J.S. Brief interventions for alcohol problems: A review. Addiction. 1993;88:315-336.
Bigelow, G.E.; Stitzer, M.L.; and Liebson, I.A. 1984.
Binder, J.L., and Strupp, H.H. 1991.
Bion, W.R. 1961.
Birchler, G.R., and Webb, L.J. Discriminating interaction behaviors in happy and unhappy marriages. Journal of Consulting and Clinical Psychology. 1977;45:494-495.
Birke, S.A.; Edelmann, R.J.; and Davis, P.E. An analysis of the abstinence violation effect in a sample of illicit drug users. British Journal of Addiction. 1990;85(10):1299-1307. [pmid: 2265290].
Blaine, J.D., and Julius, D.A., eds. 1977.
Blatt, S.J.; Quinlan, D.M.; Pilkonis, P.A.; and Shea, M.T. Impact of perfectionism and need for approval on the brief treatment of depression: The National Institute of Mental Health Treatment of Depression Collaborative Research Program revisited. Journal of Consulting and Clinical Psychology. 1995;63(1):125-132. [pmid: 7896977].
Blewett, D.B. 1969.
Bloom, B.L. 1997.
Bohart, A.C., and Todd, J. 1988.
Boorstein, S., ed. 1980.
Boszormenyi-Nagy, I., and Spark, G. 1973.
Bowen, M. Alcoholism as viewed through family systems theory and family psychology. Annals of the New York Academy of Sciences. 1974;233:115-122.
Bowen, M. 1978.
Bowlby, J. 1969.
Bradley, B.P.; Gossop, M.; Brewin, C.R.; Phillips, G.; and Green, L. Attributions and relapse in opiate addicts. Journal of Consulting and Clinical Psychology. 1992;60(3):470-472. [pmid: 1619101].
Brill, L. 1981.
Brooks, C.S.; Zuckerman, B.; Bamforth, A.; Cole, J.; and Kaplan-Sanoff, M. Clinical issues related to substance-involved mothers and their infants. Infant Mental Health Journal. 1994;15(2):202-217.
Brown, J.M., and Miller, W.R. Impact of motivational interviewing on participation and outcome in residential alcoholism treatment. Psychology of Addictive Behaviors. 1993;7:211-218.
Brown, S.A. Drug effect expectancies and addictive behavior change. Experimental and Clinical Psychopharmacology. 1993;1(1-4):55-67.
Brown, S.A.; Carrello, P.D.; Vik, P.W.; and Porter, R.J. Change in alcohol effect and self-efficacy expectancies during addiction treatment. Substance Abuse. 1998;19(4):155-167. [pmid: 12511813].
Brown, S.A.; Christiansen, B.A.; and Goldman, M.S. Alcohol Expectancy Questionnaire: An instrument for the assessment of adolescent and adult alcohol expectancies. Journal of Studies on Alcohol. 1987;48(5):483-491. [pmid: 3669677].
Budman, S.H., and Gurman, A.S. 1988.
Budney, A.J., and Higgins, S.T. 1998.
Burglass, M.E. 1971.
Burglass, M.E. 1972.
Burglass, M.E.; Bremer, D.H.; and Evans, R.J. 1976.
Burglass, M.E., and Duffy, M.G. 1974.
Burns, D.D. 1989.
Butterfield, P.S. and Leclair, S. Cognitive characteristics of bulimic and drug-abusing women. Addictive Behaviors. 1988;13(2):131-138. [pmid: 3369321].
Byington, D.B. 1997.
Cade, B., and O'Hanlon, W.H. 1993.
Campbell, J. 1968.
Campbell, T. Parental conflicts between divorced spouses: Strategies for intervention. Journal of Systemic Therapies. 1993;12(4):27-38.
Cappell, H. 1987.
Carroll, K.M. 1996.
Carroll, K.M. 1996.
Carroll, K.M.Therapy Manuals for Drug Addiction. Manual 1: A Cognitive-Behavioral Approach: Treating Cocaine Addiction.1998
Carroll, K.M.; Rounsaville, B.J.; and Gawin, F.H. A comparative trial of psychotherapies for ambulatory cocaine abusers: Relapse prevention and interpersonal psychotherapy. . American Journal of Drug and Alcohol Abuse. 1991;17:229-247.
Carson, R.C., and Butcher, J.N. 1992.
Center for Substance Abuse Treatment. 1993.
Center for Substance Abuse Treatment. 1993.
Center for Substance Abuse Treatment. 1994.
Center for Substance Abuse Treatment. 1994.
Center for Substance Abuse Treatment. 1994.
Center for Substance Abuse Treatment. 1994.
Center for Substance Abuse Treatment. 1995.
Center for Substance Abuse Treatment. 1997.
Center for Substance Abuse Treatment. 1998.
Center for Substance Abuse Treatment. 1998.
Center for Substance Abuse Treatment. 1999.
Center for Substance Abuse Treatment. 1999.
Center for Substance Abuse Treatment. 1999.
Center for Substance Abuse Treatment.
Cermak, T.L. 1986.
Chafetz, M.E.; Blane, H.T.; Abram, H.S.; Golner, J.; Lacy, E.; McCourt, W.F.; Clark, E.; and Meyers, W. Establishing treatment relationships with alcoholics. Journal of Nervous and Mental Disease. 1962;134(5):395-409. [pmid: 13877834].
Chafetz, M.E.; Hertzman, M.; and Berenson, D. 1974.
Chaney, E.F. 1989.
Chaney, E.F.; Roszell, D.K.; and Cummings, C. Relapse in opiate addicts: A behavioral analysis. Addictive Behaviors. 1982;7(3):291-297. [pmid: 7180624].
Chapman, P.L., and Huygens, I. An evaluation of three treatment programmes for alcoholism: An experimental study with 6- and 8-month follow-ups. British Journal of Addiction. 1988;83(1):67-81. [pmid: 3345384].
Chermack, S.T.; Blow, F.C.; Hill, E.M.; and Mudd, S.A. The relationship between alcohol symptoms and consumption among older drinkers. Alcoholism: Clinical and Experimental Research. 1996;20(7):1153-1158.
Chiauzzi, E.J. 1991.
Chick, J.; Lloyd, G.; and Crombie, E. Counseling problem drinkers in medical wards: A controlled study. British Medical Journal. 1985;290:965-967.
Childress, A.R.; Ehrman, R.; McLellan, A.T.; MacRae, J.; Natale, M.; and O'Brien, C.P. Can induced moods trigger drug-related responses in opiate abuse patients?. Journal of Substance Abuse Treatment. 1994;11(1):17-23. [pmid: 8201629].
Childress, A.R.; McLellan, A.T.; Ehrman, R.; and O'Brien, C.P. 1988.
Chinen, A.B. 1996.
Chopra, D. 1997.
Chutuape, M.A.; Silverman, K.; and Stitzer, M.L. Use of methadone take-home contingencies with persistent opiate and cocaine abusers. Journal of Substance Abuse Treatment. 1999;16(1):23-30. [pmid: 9888118].
Connors, G.J.; Carroll, K.M.; DiClemente, C.C.; Longabaugh, R.; and Donovan, D.M. The therapeutic alliance and its relationship to alcoholism treatment participation and outcome. Journal of Consulting and Clinical Psychology. 1997;65(4):588-598. [pmid: 9256560].
Coon, G.M.; Pena, D.; and Illich, P.A. Self-efficacy and substance abuse: Assessment using a brief phone interview. Journal of Substance Abuse Treatment. 1998;15(5): 385-391.
Cooper, J.F. 1995.
Cooper, J.F. 1998.
Copans, S. 1988.
Corey, G. 1991.
Coudert, J. 1972.
Covington, S.S. 1997.
Crawley, B. 1993.
Crits-Christoph, P. The efficacy of brief dynamic psychotherapy: A meta-analysis. American Journal of Psychiatry. 1992;149(2):151-158. [pmid: 1531169].
Crits-Christoph, P., and Barber, J.P., eds. 1991.
Crits-Christoph, P.; Barber, J.P.; and Kurcias, J.S. 1991.
Crits-Christoph, P.; Siqueland, L.; Blaine, J.; Frank, A.; Luborsky, L.; Onken, L.S.; Muenz, L.; Thase, M.E.; Weiss, R.D.; Gastfriend, D.R.; Woody, G.; Barber, J.P.; Butler, S.F.; Daley, D.; Bishop, S.; Najavits, L.M.; Lis, J.; Mercer, D.; Griffin, M.L.; Moras, K.; and Beck, A.T. The National Institute on Drug Abuse Collaborative Cocaine Treatment Study: Rationale and methods. Archives of General Psychiatry. 1997;54:721-726.
Crits-Christoph, P.; Siqueland, L.; Blaine, J.; Frank, A.; Luborsky, L.; Onken, L.S.; Muenz, L.R.; Thase, M.E.; Weiss, R.D.; Gastfriend, D.R.; Woody, G.; Barber, J.P.; Butler, S.F.; Daley, D.; Salloum, I.; Bishop, S.; Najavits, L.M.; Lis, J.; Mercer, D.; Griffin, M.L.; Moras, K.; and Beck, A.T. Psychosocial treatments for cocaine dependence: National Institute on Drug Abuse Collaborative Cocaine Treatment Study. Archives of General Psychiatry. 1999;56(6):493-502. [pmid: 10359461].
Crowley, T.J. 1984.
Cullari, S. 1998.
Cummings, C., and Gordon, J.R. 1980.
Cummings, N.A. 1990.
Daily, S.G. 1992.
Darkes, J., and Goldman, M.S. Expectancy challenge and drinking reduction: Experimental evidence for a mediational process. Journal of Consulting and Clinical Psychology. 1993;61(2):344-353. [pmid: 8473588].
Davanloo, H., ed. 1980.
Davies, J.B. 1992.
Davis, D.I.; Berenson, D.; Steinglass, P.; and Davis, S. The adaptive consequences of drinking. Psychiatry. 1974;37:209-215.
DeNelsky, G.Y., and Boat, B.W. A coping skills model of psychological diagnosis and treatment. Professional Psychology: Research and Practice. 1986;17:322-330.
Denoff, M.S. An integrated analysis of the contribution made by irrational beliefs and parental interaction to adolescent drug abuse. International Journal of the Addictions. 1988;23(7):655-659. [pmid: 3192338].
DiClemente, C.C.; Carbonari, J.P.; Montgomery, R.P.; and Hughes, S.O. The Alcohol Abstinence Self-Efficacy Scale. Journal of Studies on Alcohol. 1994;55(2):141-148. [pmid: 8189734].
DiClemente, C.C., and Fairhurst, S.K. 1995.
DiClemente, C.C.; Prochaska, J.O.; Fairhurst, S.K.; Velicer, W.F.; Velasquez, M.M.; and Rossi, J.S. The process of smoking cessation: An analysis of precontemplation, contemplation, and preparation stages of change. Journal of Consulting and Clinical Psychology. 1991;59(2):295-304. [pmid: 2030191].
DiClemente, C.C., and Scott, C.W. 1997.
Dolan, M.P.; Black, J.L.; Penk, W.E.; Rabinowitz, R.; and DeFord, H.A. Predicting the outcome of contingency contracting for drug abuse. Behavior Therapy. 1986;17:470-474.
Donovan, D.M. Assessment issues and domains in the prediction of relapse. Addiction. 1996;91(Suppl.):S29-S36.
Donovan, D.M. 1999.
Donovan, D.M., and Chaney, E.F. 1985.
Donovan, D.M., and Marlatt, G.A. 1988.
Donovan, D.M., and Marlatt, G.A. Recent developments in alcoholism: Behavioral treatment. Recent Developments in Alcoholism. 1993;11:397-411.
Dossman, R.; Kutter, P.; Heinzel, R.; and Wurmser, L. 1997.
Douglas, L.J. 1987.
Drummond, D.C. Alcohol interventions: Do the best things come in small packages?. Addiction. 1997;92(4):375-379. [pmid: 9177059].
Drummond, D.C.; Thom, B.; Brown, C.; Edwards, G.; and Mullan, M.J. Specialist versus general practitioner treatment of problem drinkers. Lancet. 1990;336(8720):915-918. [pmid: 1976937].
Edwards, G., and Orford, J. A plain treatment for alcoholism. Proceedings of the Royal Society of Medicine. 1977;70:344-348.
Edwards, G.; Orford, J.; Egert, S.; Guthrie, S.; Hawker, A.; Hensman, C.; Mitcheson, M.; Oppenheimer, E.; and Taylor, C. Alcoholism: A controlled trial of "treatment" and "advice.". Journal of Studies on Alcohol. 1977;38(5):1004-1031. [pmid: 881837].
Edwards, M.E., and Steinglass, P. Family therapy treatment outcomes for alcoholism. Journal of Marital and Family Therapy. 1995;21(4):475-509.
Ehrman, R.N.; Robbins, S.J.; Childress, A.R.; and O'Brien, C.P. Conditioned responses to cocaine-related stimuli in cocaine abuse patients. Psychopharmacology (Berl). 1992;107(4):523-529. [pmid: 1603895].
Elkin, I. 1994.
Ellis, A. The treatment of alcohol and drug abuse: A rational-emotive approach. Rational Living. 1982;17(2):15-24.
Ellis, A., and Grieger R., eds. 1977.
Ellis, A.; McInerney, J.F.; DiGiuseppe, R.; and Yeager, R.J. 1988.
Epstein, E.E., and McCrady, B.S. Behavioral couples treatment of alcohol and drug use disorders: Current status and innovations. Clinical Psychology Review. 1998;18(6):689-711. [pmid: 9779329].
Evans, D.M., and Dunn, N.J. Alcohol expectancies, coping responses and self-efficacy judgments: A replication and extension of Cooper et al.'s 1988 study in a college sample. Journal of Studies on Alcohol. 1995;56(2):186-193. [pmid: 7760565].
Fahnestock, R. 1993.
Fals-Stewart, W.; Birchler, G.R.; and O'Farrell, T.J. Behavioral couples therapy for male substance-abusing patients: Effects on relationship adjustment and drug-using behavior. Journal of Consulting and Clinical Psychology. 1996;64(5):959- 972.
Favazza, A.R., and Thompson, J.J. Social networks of alcoholics: Some early findings. Alcoholism: Clinical and Experimental Research. 1984;8(1):9-15.
Feinberg, F. 1995.
Feinstein, D., and Krippner, S. 1997.
Fisch, R.; Weakland, J.H.; and Segal, L. 1982.
Flanzer, J.P. 1989.
Flanzer, J P., and Sturkie, D.K. 1987.
Fleming, M.F.; Barry, K.L.; Manwell, L.B.; Johnson, K.; and London, R. Brief physician advice for problem drinkers: A randomized controlled trial in community-based primary care practices. JAMA. 1997;277(13):1039-1045. [pmid: 9091691].
Fleming, M.F.; Barry, K.; Manwell, L.; Johnson, K.; and London, R. A trial of early alcohol treatment (Project TrEAT): A randomized trial of brief physician advice in community-based primary care practices. JAMA. in press.
Fleming, M.F.; Manwell, L.B.; Barry, K.L.; Adams, W.; and Stauffacher, E.A. Brief physician advice for alcohol problems in older adults: A randomized community-based trial. Journal of Family Practice. 1999;48(5):378-384. [pmid: 10334615].
Flores, P. 1988.
Flores, P.J., and Mahon, L. Treatment of addiction in group psychotherapy. International Journal of Group Psychotherapy. 1993;43(2):143-156. [pmid: 8473058].
Flores-Ortiz, Y., and Bernal, G. Contextual family therapy of addiction with Latinos. Journal of Psychotherapy and the Family. 1989;6(1-2):123-142.
Folkman, S., and Lazarus, R.S. Coping as a mediator of emotion. Journal of Personality and Social Psychology. 1988;54(3):466-475. [pmid: 3361419].
Folkman, S., and Lazarus, R.S. 1991.
Frankel, A.J. Groupwork with recovering families in concurrent parent and children's groups. Alcoholism Treatment Quarterly. 1992;9(3-4):23-37.
Frawley, P.J., and Smith, J.W. Chemical aversion therapy in the treatment of cocaine dependence as part of a multimodal treatment program: Treatment outcome. Journal of Substance Abuse Treatment. 1990;7(1):21-29. [pmid: 2313768].
Freeman, A.; Pretzer, J.M.; Fleming, B.; Simon, K.M. 1990.
Freeman, A., and Reinecke, M.A. 1993.
French, S. Family approaches to alcoholism: Why the lack of interest among marriage and family professionals?. Journal of Drug Issues. 1987;17(4):359-368.
Friedberg, L.M. 1999.
Friedman, A.S. 1990.
Fromme, K.; Stroot, E.; and Kaplan, D. Comprehensive effects of alcohol: Development and psychometric assessment of a new expectancy questionnaire. Psychological Assessment. 1993;5(1):19-26.
Gabbard, G.O.; Lazar, S.G.; Hornberger, J.; and Spiegel, D. The economic impact of psychotherapy: A review. American Journal of Psychiatry. 1997;154:147-155.
Galanter, M. 1993.
Galanter, M.; Keller, D.S.; and Dermatis, H. Network Therapy for addiction: Assessment of the clinical outcome of training. American Journal of Drug and Alcohol Abuse. 1997;23(3):355-367. [pmid: 9261485].
Gambrill, E. 1981.
Garvin, C.D.; Reid, W.; and Epstein, L. 1976.
Gerstein, D.R., and Harwood, J.H., eds. 1990.
Giorgi, A., ed. 1985.
Giorlando, M., and Schilling, R.J. On becoming a solution-focused physician: The MED-STAT acronym. Families, Systems and Health. 1996;14(4): 361-371.
Goldman, M.S. The alcohol expectancy concept: Applications to assessment, prevention, and treatment of alcohol abuse. Applied and Preventive Psychology. 1994;3(3):131-144.
Goldman, M.S., and Brown, S.A. 1987.
Goldman, M.S., and Rather, B.C. 1993.
Gomberg, E.S. Women and alcohol: Use and abuse. Journal of Nervous and Mental Disease. 1993;181(4): 211-219.
Gomberg, E.S.; Nelson, B.W.; and Hatchett, B.F. Women, alcoholism, and family therapy. Family and Community Health. 1991;13(4):61-71.
Gorad, S.L.; McCourt, W.F.; and Cobb, J.C. A communications approach to alcoholism. Quarterly Journal of Studies on Alcohol. 1971;32:651-668.
Gottheil, E.; Weinstein, S.P.; Sterling, R.C.; Lundy, A.; and Serota, R.D. A randomized controlled study of the effectiveness of intensive outpatient treatment for cocaine dependence. Psychiatric Services. 1998;49(6):782-787. [pmid: 9634157].
Grenyer, B.F.; Luborsky, L.; and Solowij, N. 1995.
Grenyer, B.F.; Solowij, N.; and Peters, R. 1996.
Grof, S. 1985.
Hales, R.E.; Yudofsky, S.C.; and Talbott, J.A., eds. 1994.
Haley, J. 1963.
Haley, J. 1973.
Haley, J. 1976.
Haley, J. 1987.
Harris, K.B., and Miller, W.R. Behavioral self-control training for problem drinkers: Components of efficacy. Psychology of Addictive Behaviors. 1990;4(2):90-92.
Hart, T. Inspiration: Exploring the experience and its meaning. Journal of Humanistic Psychology. 1998;38(3):7-35.
Hawkins, R.C., II. 1992.
Heather, N. Brief interventions on the world map. Addiction. 1994;89(6):665-667.
Heather, N. Interpreting the evidence on brief interventions for excessive drinkers: The need for caution. Alcohol and Alcoholism. 1995;30(3):287-296. [pmid: 7545982].
Heather, N.; Campion, P.D.; Neville, R.G.; and MacCabe, D. Evaluation of a controlled drinking minimal intervention for problem drinkers in general practice (the DRAMS scheme). Journal of the Royal College of General Practitioners. 1987;37:358-363.
Henggeler, S.W.; Pickrel, S.G.; Brondino, M.J.; and Crouch, J.L. Eliminating (almost) treatment dropout of substance abusing or dependent delinquents through home-based multisystemic therapy. American Journal of Psychiatry. 1996;153(3):427-428. [pmid: 8610836].
Herdman, J.W. 1997.
Hester, R.K. 1995.
Hester, R.K., and Delaney, H.D. Behavioral Self-Control Program for Windows: Results of a controlled clinical trial. Journal of Consulting and Clinical Psychology. 1997;65(4):686-693. [pmid: 9256570].
Hester, R.K., and Miller, W.R. 1989.
Higgins, S.T. The influence of alternative reinforcers on cocaine use and abuse: A brief review. Pharmacological and Biochemical Behaviors. 1997;57(3):419-427.
Higgins, S.T. 1999.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Foerg, F.E.; Donham, R.; and Badger, M.S. Incentives improve outcome in outpatient behavioral treatment of cocaine dependence. Archives of General Psychiatry. 1994;51:568-576.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Badger, G. Achieving cocaine abstinence with a behavioral approach. . American Journal of Psychiatry. 1993;150(5):763-769. [pmid: 8480823].
Higgins, S.T.; Delaney, D.D.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Fenwick, J.W. A behavioral approach to achieving initial cocaine abstinence. American Journal of Psychiatry. 1991;148(9):1218-1224. [pmid: 1883001].
Higgins, S.T.; Tidey, J.W.; and Stitzer, M.L. 1998.
Higgins-Biddle, J.C.; Babor, T.F.; Mullahy, J.; Daniels, J.; and McRee, B. Alcohol screening and brief intervention: Where research meets practice. Connecticut Medicine. 1997;61(9):565-575. [pmid: 9334512].
Hill, A. 1989.
Hodgins, D.C.; Leigh, G.; Milne, R.; and Gerrish, R. Drinking goal selection in behavioral self-management treatment of chronic alcoholics. Addictive Behaviors. 1997;22(2):247-255. [pmid: 9113218].
Hodgson, R., and Rollnick, S. 1991.
Holder, H.; Longabaugh, R.; Miller, W.R.; and Rubonis, A.V. The cost effectiveness of treatment for alcoholism: A first approximation. Journal of Studies on Alcohol. 1991;52(6):517-540. [pmid: 1661799].
Hollon, S.D., and Beck, A.T. 1994.
Horowitz, M.J. 1991.
Horvath, A.O., and Greenberg, L.S., eds. 1994.
Howard, M.O.; Elkins, R.L.; Rimmele, C.; and Smith, J.W. Chemical aversion treatment of alcohol dependence. Drug and Alcohol Dependence. 1991;29(2):107-143. [pmid: 1797524].
Hoyt, M.F. 1995.
Hser, Y.I.; Joshi, V.; Anglin, M.D.; and Fletcher, B. Predicting posttreatment cocaine abstinence for first-time admissions and treatment repeaters. American Journal of Public Health. 1999;89(5):666-671. [pmid: 10224976].
Hubbard, R.L.; Craddock, S.G.; Flynn, P.M.; Anderson, J.; and Etheridge, R.M. Overview of 1-year outcomes in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behaviors. 1997;11(4):261-278.
Hunt, G.M., and Azrin, N.H. A community-reinforcement approach to alcoholism. Behaviour Research and Therapy. 1973;11(1):91-104. [pmid: 4781962].
ICD-9-CM: The International Classification of Diseases, 9th Revision, Clinical Modification. 1995.
Iguchi, M.Y.; Belding, M.A.; Morral, A.R.; Lamb, R.J.; Husband, S.D. Reinforcing operants other than abstinence in drug abuse treatment: An effective alternative for reducing drug use. Journal of Consulting and Clinical Psychology. 1997;65(3):421-428. [pmid: 9170765].
Institute of Medicine. 1990.
Institute of Medicine. 1996.
Jackson, J. The adjustment of the family to the crisis of alcoholism. . Quarterly Journal of Studies on Alcohol. 1954;15:562-586.
Jaffe, A.J., and Kilbey, M.M. The Cocaine Expectancy Questionnaire (CEQ): Construction and predictive utility. Psychological Assessment. 1994;6(1):18-26.
Janis, I.L., and Mann, L. 1977.
Jarvis, T.J. Implications of gender for alcohol treatment research: A quantitative and qualitative review. British Journal of Addiction. 1992;87(9):1249-1261. [pmid: 1392550].
Jesse, R.C. 1989.
Johnson, R. 1987.
Johnson, V.E. 1973.
Johnson, V.E. 1986.
Jones, B.T., and McMahon, J. Negative alcohol expectancy predicts post-treatment abstinence survivorship: The whether, when and why of relapse to a first drink. Addiction. 1994;89(12):1653-1665. [pmid: 7866249].
Jones, B.T., and McMahon, J. Negative and positive alcohol expectancies as predictors of abstinence after discharge from a residential treatment program: A one-month and three-month follow-up study in men. Journal of Studies on Alcohol. 1994;55(5):543-548. [pmid: 7990464].
Jones, B.T., and McMahon, J. A comparison of positive and negative alcohol expectancy and value and their multiplicative composite as predictors of post-treatment abstinence survivorship. Addiction. 1996;91(1):89-99. [pmid: 8822017].
Jones, B.T., and McMahon, J. 1998.
Juhnke, G.A., and Coker, J.K. Solution-focused intervention with recovering, alcohol-dependent, single parent mothers and their children. Journal of Addictions and Offender Counseling. 1997;17(2):77-87.
Kadden, R.; Carroll, K.; Donovan, D.; Cooney, N.; Monti, P.; Abrams, D.; Litt, M.; and Hester, R., eds. 1992.
Kahan, M.; Wilson, L.; and Becker, L. Effectiveness of physician-based interventions with problem drinkers: A review. Canadian Medical Association Journal. 1995;152(6):851-859. [pmid: 7697578].
Kang, S.Y.; Kleinman, P.H.; Woody, G.E.; Millman, R.B.; Todd, T.C.; Kemp, J.; and Lipton, D.S. Outcomes for cocaine abusers after once-a-week psychosocial therapy. American Journal of Psychiatry. 1991;148(5):630-635. [pmid: 1850208].
Kaplan, H., and Sadock, B., eds. 1995.
Katz, R. 1993.
Kaufman, E., and Borders, L. 1988.
Kaufman, E., and Kaufmann, P. 1979.
Kay, J. Brief psychodynamic psychotherapies: Past, present, and future challenges. Journal of Psychotherapy Practice and Research. 1997;6(4):330-337. [pmid: 9292447].
Keller, D.S.; Galanter, M.; and Weinberg, S. Validation of a scale for network therapy: A technique for systematic use of peer and family support in addiction treatment. American Journal of Drug and Alcohol Abuse. 1997;23(1):115-127. [pmid: 9048151].
Kendall, P.C., and Turk, D.C. 1984.
Khantzian, E.J. The self-medication hypothesis of addictive disorders: Focus on heroin and cocaine dependence. American Journal of Psychiatry. 1985;142(11):1259-1264. [pmid: 3904487].
Khantzian, E.J.; Halliday, K.S.; and McAuliffe, W.E. 1990.
Kirby, K.C.; Marlowe, D.B.; Festinger, D.S.; Lamb, R.J.; and Platt, J.J. Schedule of voucher delivery influences initiation of cocaine abstinence. Journal of Consulting and Clinical Psychology. 1998;66:761-767.
Kirmil-Gray, K.; Eagleston, J.R.; Thoresen, C.E.; and Zarcone, V.P., Jr. Brief consultation and stress management treatments for drug-dependent insomnia: Effects on sleep quality, self-efficacy, and daytime stress. Journal of Behavioral Medicine. 1985;8(1):79-99. [pmid: 3981628].
Kleber, H.D., and Gawin, F.H. 1984.
Kleinman, P.H.; Woody, G.E.; Todd, T.C.; Millman, R.B.; Kang, S.; Kemp, J.; and Lipton, D.S. 1990.
Klerman, G.L., and Weissman, M.M., eds. 1993.
Klerman, G.L.; Weissman, M.M.; and Rounsaville, B.J. 1984.
Koss, M.P.; Butcher, J.N.; and Strupp, H.H. Brief psychotherapy methods in clinical research. Journal of Consulting and Clinical Psychology. 1986;54:60-67.
Koss, M.P., and Shiang, J. 1994.
Krampen, G. Motivation in the treatment of alcoholism. Addictive Behaviors. 1989;14:197-200.
Kristenson, H.; Ohlin, H.; Hulten-Nosslin, B.; Trell, E.; and Hood, B. Identification and intervention of heavy drinking in middle-aged men: Results and follow-up of 24-60 months of long-term study with randomized controls. . Alcoholism: Clinical and Experimental Research. 1983;7(2):203-209.
Kristenson, H., and Osterling, A. Problems and possibilities. Addiction. 1994;89(6):671-674.
Krystal, H. Aspects of affect theory. Bulletin of the Menninger Clinic. 1977;41:1-26.
Kymissis, P.; Bevacqua, A.; and Morales, N. Multi-family group therapy with dually diagnosed adolescents. Journal of Child and Adolescent Group Therapy. 1995;5(2):107-113.
Laikin, M.; Winston, A.; and McCullough, L. 1991.
Lamb, S.; Greenlick, M.R.; and McCarty, D. 1998.
Lambert, M.J., and Bergin, A.E. 1994.
Landry, M.J. 1996.
Larimer, M.E., and Marlatt, G.A. Applications of relapse prevention with moderation goals. Journal of Psychoactive Drugs. 1990;22(2):189-195. [pmid: 2197393].
Laureano, M., and Poliandro, E. Understanding cultural values of Latino male alcoholics and their families: A culture sensitive model. Journal of Chemical Dependency Treatment. 1991;4(1):137-155.
Lazarus, R.S. Coping theory and research: Past, present, and future. Psychosomatic Medicine. 1993;55(3):234-247. [pmid: 8346332].
Leeds J., and Morgenstern, J. 1996.
Lemere, F. Aversion treatment of alcoholism: Some reminiscences. British Journal of Addiction. 1987;82(3):257-258. [pmid: 3471256].
Levenson, H.; Butler, S.F.; and Beitman, B.D. 1997.
Levin, J.D. 1987.
Levine, B. 1967.
Levine, B., and Gallogly, V. 1985.
Lewinsohn, P.M.; Clarke, G.N.; Hops, H.; and Andrews, J.A. Cognitive-behavioral treatment for depressed adolescents. Behavior Therapy. 1990;21:385-401.
Lewis, M.L. Alcoholism and family casework. Social Casework. 1937;35:8-14.
Liddle, H.A., and Dakof, G.A. 1994.
Liddle, H.A., and Dakof, G.A. Efficacy of family therapy for drug abuse: Promising but not definitive. Journal of Marital and Family Therapy. 1995;21(4):511-543.
Liddle, H.A.; Dakof, G.; Diamond, G.; Holt, M.; Aroyo, J.; and Watson, M. 1992.
Linehan, M.M. 1993.
Litman, G.K. 1986.
Locke, H., and Wallace, K. Short marital adjustment and prediction tests: Their reliability and validity. Marriage and Family Living. 1959;21:251-255.
Lowinson, J.H.; Ruiz, P.; and Millman, R.B. 1997.
Luborsky, L. 1984.
Luborsky, L., and Mark, D. 1991.
Luborsky, L.; McLellan, T.A.; Woody, G.E.; O'Brien, C.P.; and Auerbach, A. Therapist success and its determinants. Archives of General Psychiatry. 1985;42:602-611.
Luborsky, L.; Woody, G.E.; Hole, A.V.; and Velleco, A. 1989.
Luborsky, L.; Woody, G.E.; Hole, A.V.; and Velleco, A. 1995.
Lyons, L.C., and Woods, P.J. The efficacy of rational-emotive therapy: A quantitative review of the outcome research. Clinical Psychology Review. 1991;11:357-369.
Lyotard, J.F. 1984.
Mackay, P.W., and Donovan, D.M. 1991.
MacKenzie, R.K. 1990.
Magura, S.; Casriel, C.; Goldsmith, D.S.; and Lipton, D.S. Contracting with clients in methadone treatment. Social Casework. 1987;68:485-493.
Magura, S.; Casriel, C.; Goldsmith, D.S.; Strug, D.L.; Lipton, D.S. Contingency contracting with polydrug-abusing methadone patients. Addictive Behaviors. 1988;13(1):113-118. [pmid: 3284282].
Malan, D.H. 1976.
Mangione, T.W.; Howland, J.; Amick, B.; Cote, J.; Lee, M.; Bell, N.; Levine, S. Employee drinking practices and work performance. Journal of Studies on Alcohol. 1999;60(2):261-270. [pmid: 10091965].
Manisses Communications Group. Group therapy works well for addiction: Identifying with others in group leads to self-awareness. Behavioral Health Treatment. 1997;2(1):1.
Manisses Communications Group. Researchers tout marital therapy for alcohol problems. Alcoholism and Drug Abuse Week. 1997;9(23), 6.
Manisses Communications Group. Study: Group therapy helps addicted women with abuse history. Alcoholism and Drug Abuse Week. 1997;9(33):5-6.
Mann, J. 1973.
Mann, J. 1991.
Mann, J., and Goldman, R. 1994.
Marcus, B.H.; Selby, V.C.; Niaura, R.S.; and Rossi, J.S. Self-efficacy and the stages of exercise behavior change. Research Quarterly for Exercise and Sport. 1992;63(1):60-66. [pmid: 1574662].
Mark, D., and Faude, J. 1995.
Mark, D., and Faude, J. 1997.
Mark, D., and Luborsky, L. 1992.
Marlatt, G.A. 1978.
Marlatt, G.A. Section I: Theoretical perspectives on relapse. Taxonomy of high-risk situations for alcohol relapse: Evolution and development of a cognitive-behavioral model. Addiction. 1996;91(Suppl.):S37-S49.
Marlatt, G.A.; Baer, J.S.; Donovan, D.M.; and Kivlahan, D.R. Addictive behaviors: Etiology and treatment. Annual Review of Psychology. 1988;39:223-252.
Marlatt, G.A., and Donovan, D.M. 1981.
Marlatt, G.A., and Gordon, J.R. 1980.
Marlatt, G.A., and Gordon, J.R. 1985.
Marlatt, G.A.; Somers, J.M.; and Tapert, S.F. 1993.
Maslow, A.H. 1968.
Maslow, A.H. 1987.
Matano, R.A., and Yalom, I.R. Approaches to chemical dependency: Chemical dependency and interactive group therapy: A synthesis. International Journal of Group Psychotherapy. 1991;41(3):269-293. [pmid: 1885248].
Mattick, R.P., and Jarvis, T. Brief or minimal intervention for 'alcoholics'? The evidence suggests otherwise. Drug and Alcohol Review. 1994;13:137-144.
Maultsby, M.C. 1976.
May, G.G. 1991.
May, R., and Yalom, I. Existential psychotherapy. In: Corsini, R.J., and Wedding, D., eds. Current Psychotherapies. 1995;5th ed. Itasca, IL: F.E. Peacock.
McCrady, B.S. Outcomes of family-involved alcoholism treatment. In: Galanter, M., ed. Recent Developments in Alcoholism. 1989;Vol. 7. New York: Plenum Press.
McCrady, B.S. Promising but underutilized treatment approaches. Alcohol Health & Research World. 1991;15(3):215-218.
McCrady, B.S. 1993.
McCrady, B.S.; Noel, N.E.; Abrams, D.B.; Stout, R.L.; Nelson, H.F; and Hay, W.M. Comparative effectiveness of three types of spouse involvement in outpatient behavioral alcoholism treatment. Journal of Studies on Alcohol. 1986;47(6):459-467. [pmid: 3795960].
McCrady, B.S.; Stout, R.; Noel, N.; Abrams, D.; and Nelson, H. Effectiveness of three types of spouse-involved behavioral alcoholism treatment. British Journal of Addiction. 1991;86(11):1415-1424. [pmid: 1777736].
McGoldrick, M.; Giordano, J.; and Pearce, J.K. 1996.
McLellan A.T.; Arndt, I.O.; Metzger, D.S.; Woody, G.E.; and O'Brien, C.P. The effects of psychosocial services in substance abuse treatment. JAMA. 1993;269(15):1953-1959. [pmid: 8385230].
McMahon, J., and Jones, B.T. Negative expectancy in motivation. Addiction Research. 1993;1(2):145-155.
McMahon, J., and Jones, B.T. Post-treatment abstinence survivorship and motivation for recovery: The predictive validity of the Readiness to Change (RCQ) and Negative Alcohol Expectancy (NAEQ) Questionnaires. Addiction Research. 1996;4(2):161-176.
McMullin, R.E. 1986.
Messer, S.B., and Warren, C.S. 1995.
Meyers, R.J.; Dominguez, T.P.; and Smith, J.E. 1996.
Meyers, R.J., and Smith, J.E. 1995.
Meyers, R.J., and Smith, J.E. Getting off the fence: Procedures to engage treatment-resistant drinkers. Journal of Substance Abuse Treatment. 1997;14:467-472.
Meyers, R.J.; Smith, J.E.; and Miller, E.J. 1998.
Michaelec, E.M.; Rohsenow, D.J.; Monti, P.M.; Varney, S.M.; Martin, R.A.; Dey, A.N.; Myers, M.G.; and Sirota, A.D. Cocaine Negative Consequences Checklist: Development and validation. Journal of Substance Abuse. 1996;8(2):181-193. [pmid: 8880659].
Midanik, L. The validity of self-reported alcohol consumption and alcohol problems: A literature review. British Journal of Addiction. 1982;77(4):357-382. [pmid: 6762224].
Middelkoop, P. 1989.
Milby, J.B.; Schumacher, J.E.; Raczynski, J.M.; Caldwell, E.; Engle, M.; Michael, M.; and Carr, J. Sufficient conditions for effective treatment of substance abusing homeless persons. Drug and Alcohol Dependence. 1996;43(1-2):39-47.
Miller, N.S., ed. 1991.
Miller, S.D. The resistant substance abuser: Court mandated cases can pose special problems. Commentary: A solution-focused approach. Networker. 1992;16(1):83-87.
Miller, S.D. 1994.
Miller, S.D., and Berg, I. Working with the problem drinker: A solution-focused approach. Arizona Counseling Journal. 1991;16(1):3-12.
Miller, W.R. 1993.
Miller, W.R.; Benefield, R.G.; and Tonigan, J.S. Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting and Clinical Psychology. 1993;61:455-461.
Miller, W.R.; Brown, J.M.; Simpson, T.L.; Handmaker, N.S.; Bien, T.H.; Luckie, L.F.; Montgomery, H.A.; Hester, R.K.; and Tonigan, J.S. 1995.
Miller, W.R.; Gribskov, C.J.; and Mortell, R.L. Effectiveness of a self-control manual for problem drinkers with and without therapist contact. International Journal of the Addictions. 1981;16(7):1247-1254. [pmid: 7327785].
Miller, W.R., and Hester, R.K. Inpatient alcoholism treatment: Who benefits?. American Psychologist. 1986;41(7): 794-805.
Miller, W.R., and Hester, R.K. 1986.
Miller, W.R.; Jackson, K.A.; and Karr, K.W. Alcohol problems: There's a lot you can do in two or three sessions. EAP Digest. 1994;14:18-21, 35-36.
Miller, W.R., and Munoz, R.F. 1982.
Miller, W.R., and Rollnick, S. 1991.
Miller, W.R., and Sanchez, V.C. 1994.
Miller, W.R., and Sovereign, R.G. 1989.
Miller, W.R., and Taylor, C.A. Relative effectiveness of bibliotherapy, individual and group self-control training in the treatment of problem drinkers. Addictive Behaviors. 1980;5:13-24.
Miller, W.R.; Taylor, C.A.; and West, J.C. Focused versus broad-spectrum behavior therapy for problem drinkers. Journal of Consulting and Clinical Psychology. 1980;48(5):590-601. [pmid: 7410657].
Mintz, J.; Mintz, L.I.; Arruda, M.J.; and Hwang, S.S. Treatments of depression and the functional capacity to work. Archives of General Psychiatry. 1992;49(10):761-768. [pmid: 1417427].
Minuchin, S. 1974.
Minuchin, S., and Fishman, H.C. 1981.
Monti, P.M.; Abrams, D.B.; Kadden, R.M.; and Cooney, N.L. 1989.
Monti, P.M.; Gulliver, S.B.; and Myers, M.G. Social skills training for alcoholics: Assessment and treatment. Alcohol and Alcoholism. 1994;29(6):627-637. [pmid: 7695776].
Monti, P.M.; Rohsenow, D.J.; Colby, S.M.; and Abrams, D.B. 1995.
Monti, P.M.; Rohsenow, D.J.; Michaelec, E.; Martin, R.A.; and Abrams, D.B. Brief coping skills treatment for cocaine abuse: Substance use outcomes at three months. Addiction. 1997;92(12):1717-1728. [pmid: 9581004].
Moser, A.E., and Annis, H.M. The role of coping in relapse crisis outcome: A prospective study of treated alcoholics. Addiction. 1996;91(8):1101-1114. [pmid: 8828239].
Moyer, M.A. Achieving successful chemical dependency recovery in veteran survivors of traumatic stress. Alcoholism Treatment Quarterly. 1988;4(4):19-34.
Mudd, S.A.; Blow, F.C.; Walton, M.A.; Snedecor, S.M.; and Nord, J.L. Stages of change in elderly substance abusers. Alcohol: Clinical and Experimental Research. 1995;19 (Suppl.):90a.
Myers, M.G.; Martin, R.A.; Rohsenow, D.J.; and Monti, P.M. The Relapse Situation Appraisal Questionnaire: Initial psychometric characteristics and validation. Psychology of Addictive Behaviors. 1996;10(4):237-247.
Najavits, L.M.; Weiss, R.D.; and Liese, B.S. Group cognitive-behavioral therapy for women with PTSD and substance use disorder. Journal of Substance Abuse Treatment. 1996;13(1):13-22. [pmid: 8699538].
National Institute on Alcohol Abuse and Alcoholism (NIAAA).NIAAA, 1995.
Neidigh, L.W.; Gesten, E.L.; and Shiffman, S. Coping with the temptation to drink. Addictive Behaviors. 1988;13(1):1-9. [pmid: 3364216].
Nelson, J.E. 1994.
Nezu, A.M. Efficacy of a social problem-solving therapy approach for unipolar depression. Journal of Consulting and Clinical Psychology. 1986;54(2):196-202. [pmid: 3700806].
Nichols, M.P., and Schwartz, R.C. 1998.
Nicholson, T.; Higgins, W.; Turner, P.; James, S.; Stickle, F.; and Pruitt, T. The relation between meaning in life and the occurrence of drug abuse: A retrospective study. Psychology of Addictive Behaviors. 1994;8(1):24-28.
Nielsen, G., and Barth, K. 1991.
Nietzel, M.T., ed. 1998.
Noel, N., and McCrady, B. 1993.
O'Brien, C.P., and Childress, A.R. 1992.
O'Brien, C.P.; Childress; A.R.; McClellan, T.; and Ehrman, R. Integrating systemic cue exposure with standard treatment in recovering drug dependent patients. Addictive Behaviors. 1990;15(4):355-365. [pmid: 2248109].
O'Farrell, T.J., and Bayog, R.D. Antabuse contracts for married alcoholics and their spouses: A method to maintain antabuse ingestion and decrease conflict about drinking. Journal of Substance Abuse Treatment. 1986;3:1-8.
O'Farrell, T.J.; Choquette, K.A.; Cutter, H.S.; Brown, E.D.; and McCourt, W.F. Behavioral marital therapy with and without additional couples relapse prevention sessions for alcoholics and their wives. Journal of Studies on Alcohol. 1993;54:652-666.
O'Farrell, T.J., and Cowles, K.S. 1989.
O'Farrell, T.J.; Cutter, H.S.; and Floyd, F.J. Evaluating behavioral marital therapy for male alcoholics: Effects on marital adjustment and communication from before to after treatment. Behavior Therapy. 1985;16:147-167.
O'Malley, S.S.; Jaffe, A.J.; Chang, G.; Schottenfeld, R.S.; Meyer, R.E.; and Rounsaville, B.J. Naltrexone and coping skills therapy for alcohol dependence: A controlled study. Archives of General Psychiatry. 1992;49:881-887.
O'Malley, S.S., and Kosten, T.R. Couples therapy with cocaine abusers. Family Therapy Collections. 1988;25:121-131.
Orford, J.; Guthrie, S.; Nicholls, P.; Oppenheimer, E.; Egert, S.; and Hensman, C. Self-reported coping behavior of wives of alcoholics and its association with drinking outcome. Journal of Studies on Alcohol. 1975;36:1254-1267.
Orford, J.; Oppenheimer, E.; and Edwards, G. Abstinence or control: The outcome for excessive drinkers two years after consultation. Behavior Research and Therapy. 1976;14:409-418.
O'Sullivan, C.M. 1989.
Ouimette, P.C.; Finney, J.W.; and Moos, R.H. Twelve-step and cognitive-behavioral treatment for substance abuse: A comparison of treatment effectiveness. Journal of Clinical and Consulting Psychology. 1997;65:230-240.
Panitz, D.R.; McConchie, R.D.; Sauber, S R.; and Fonseca, J.A. The role of machismo and the Hispanic family in the etiology and treatment of alcoholism in Hispanic American males. American Journal of Family Therapy. 1983;11(1):31-44.
Papp, P. 1977.
Papp, P. 1983.
Parad, H.J., and Libbie, G., eds. 1990.
Parker, R., and Horton, H. A typology of ritual: Paradigms for healing and empowerment. Counseling and Values. 1996;40:82-97.
Peake, T.H.; Borduin, C.M.; and Archer, R.P. 1988.
Pekarik, G., and Wierzbicki, M. The relationship between clients' expected and actual treatment duration. Psychotherapy. 1986;23:532-534.
Perls, F. 1969.
Persson, J., and Magnusson, P.H. Early intervention in patients with excessive consumption of alcohol: A controlled study. Alcohol. 1989;6(5):403-408. [pmid: 2573364].
Phillips, E.L. The ubiquitous decay curve: Service delivery similarities in psychotherapy, medicine, and addiction. Professional Psychology: Research and Practice. 1987;18:650-652.
Phillips, E.L., and Weiner, D.N. 1966.
Piazza, J., and DelValle, C.M. Community-based family therapy training: An example of work with poor and minority families. Journal of Strategic and Systemic Therapies. 1992;11(2):53-69.
Pine, F. 1990.
Pinsker, H.; Rosenthal, R.; and McCullough, L. 1991.
Pollack, J.; Flegenheimer, W.; and Winston, A. 1991.
Polster, I., and Polster, M. 1973.
Prochaska, J.O. 1999.
Prochaska, J.O., and DiClemente, C.C. 1984.
Prochaska, J.O., and DiClemente, C.C. 1986.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. 1992.
Prochaska, J.O.; Velicer, W.F.; Rossi, J.S.; Goldstein, M.G.; Marcus, B.H.; Rakowski, W.; Fiore, C.; Harlow, L.L.; Redding, C.A.; and Rosenbloom, D. Stages of change and decisional balance for 12 problem behaviors. Health Psychology. 1994;131(1):39-46.
Project MATCH Research Group. Matching alcoholism treatments to client heterogeneity: Project MATCH posttreatment drinking outcomes. Journal of Studies on Alcohol. 1997;58(1):7-29. [pmid: 8979210].
Project MATCH Research Group. Matching alcoholism treatments to client heterogeneity: Project MATCH three-year drinking outcomes. Alcoholism: Clinical and Experimental Research. 1998;22(6):1300-1311.
Rapp, C., and Wintersteen, R. The strengths model of case management: Results from twelve demonstrations. Psychosocial Rehabilitation Journal. 1989;13(1): 23-32.
Rathbone-McCuan, E., and Hedlund, J. Older families and issues of alcohol misuse: A neglected problem in psychotherapy. Journal of Psychotherapy and the Family. 1989;5(1-2):173-184.
Ratner, H., and Yandoli, D. 1996.
Read, M.R.; Penick, E.C.; and Nickel, E.J. 1993.
Regan, J.M.; Connors, G.J.; O'Farrell, T.J.; and Jones, W.C. Services for the families of alcoholics: A survey of treatment agencies in Massachusetts. Journal of Studies on Alcohol. 1983;44(6):1072-1082. [pmid: 6664086].
Rehm, L.P.; Fuchs, C.Z.; Roth, D.M.; Kornblith, S.J.; and Romano, J.M. A comparison of self-control and assertion skills treatments of depression. Behavior Therapy. 1979;10:429-442.
Reich, J.W., and Gutierres, S.E. Life event and treatment attributions in drug abuse and rehabilitation. American Journal of Drug and Alcohol Abuse. 1987;131(2):73-94.
Reilly, P.G. Assessment and treatment of the mentally ill chemical abuser and the family. Journal of Chemical Dependency Treatment. 1991;4(1):167-178.
Reilly, P.M.; Sees, K.L.; Shopshire, M.S.; Hall, S.M.; Delucchi, K.L.; Tusel, D.J.; Banys, P.; Clark, H.W.; and Piotrowski, N.A. Self-efficacy and illicit opioid use in a 180-day methadone detoxification treatment. Journal of Consulting and Clinical Psychology. 1995;63(1):158-162. [pmid: 7896984].
Rice-Licare, J., and Delaney-McLoughlin, K. 1990.
Rimmele, C.T.; Howard, M.O.; and Hilfrink, M.L. 1995.
Roberts, R.W., and Northen, H. 1976.
Rohsenow, D.J., and Monti, P.M. 1995.
Rohsenow, D.J.; Monti, P.M.; Zwick, W.R.; Nirenberg, T.D.; Liepman, M.R.; Binkoff, J.A.; and Abrams, D.B. Irrational beliefs, urges to drink and drinking among alcoholics. Journal of Studies on Alcohol. 1989;50(5):461-464. [pmid: 2779249].
Rohsenow, D.J.; Niaura, R.S.; Childress, A.R.; Abrams, D.B.; and Monti, P.M. Cue reactivity in addictive behaviors: Theoretical and treatment implications. International Journal of the Addictions. 1991;25(7A-8A):957-993.
Romach, M.K., and Sellers, E.M. 1998.
Ross, S.M.; Miller, P.J.; Emmerson, R.Y.; and Todt, E.H. Self-efficacy, standards, and abstinence violation: A comparison between newly sober and long-term sober alcoholics. Journal of Substance Abuse. 1988-1989;1(2):221-229.
Rotgers, F. 1996.
Rotunda, R.J., and O'Farrell, T.J. 1997.
Rounds-Bryant, J.L.; Flynn, P.M.; and Craighead, L.W. Relationship between self-efficacy perceptions and in-treatment drug use among regular cocaine users. American Journal of Drug and Alcohol Abuse. 1997;23(3):383-395. [pmid: 9261487].
Rounsaville, B.J., and Carroll, K.M. 1993.
Rounsaville, B.J.; Glazer, W.; Wilber C.H.; Weissman, M.M.; and Kleber, H.D. Short-term interpersonal psychotherapy in methadone-maintained opiate addicts. Archives of General Psychiatry. 1983;40: 629-636.
Rowan, J. 1993.
Rush, J., ed. 1982.
Ryglewicz, H. Psychoeducation for clients and families: A way in, out, and through in working with people with dual disorders. Psychosocial Rehabilitation Journal. 1991;15(2):79-89.
Saleebey, D. The strengths perspective in social work practice: Extensions and cautions. Social Work. 1996;44(3):296-305.
Sanchez-Craig, M. 1995.
Sanchez-Craig, M. Toward a public health model to preventing alcohol problems. Addiction. 1994;89(6):660-662.
Sanchez-Craig, M.; Annis, H.M.; Bornet, A.R.; and MacDonald, K.R. Random assignment to abstinence and controlled drinking: Evaluation of a cognitive-behavioral program for problem drinkers. Journal of Consulting and Clinical Psychology. 1984;52(3):390-403. [pmid: 6747058].
Sanchez-Craig, M.; Neumann, B.; Souza-Formigoni, M.; and Rieck, L. Brief treatment for alcohol dependence: Level of dependence and treatment outcome. Alcohol and Alcoholism. 1991;(Suppl. 1):515-518.
Santisteban, D.A., and Szapocznik, J. Bridging theory, research and practice to more successfully engage substance abusing youth and their families into therapy. Journal of Child and Adolescent Substance Abuse. 1994;3(2): 9-24.
Sapiro, V. 1990.
Saunders, B.; Wilkinson, C.; and Phillips, M. The impact of brief motivational intervention with opiate users attending a methadone programme. Addiction. 1995;90:415-424.
Schafer, J., and Brown, S.A. Marijuana and cocaine effect expectancies and drug use patterns. Journal of Consulting and Clinical Psychology. 1991;59(4):558-565. [pmid: 1918560].
Schmidt, S.E.; Liddle, H.A.; and Dakof, G.A. Changes in parenting practices and adolescent drug abuse during multidimensional family therapy. Journal of Family Psychology. 1996;10(1): 12-27.
Schneider, R.; Casey, J.; and Kohn, R. Motivational versus confrontational interviewing: A comparison of substance abuse assessment practices at employee assistance programs. Journal of Behavioral Health Services and Research. in press.
Schuster, C.R., and Silverman, K. 1993.
Schutt, M. 1985.
Schor, L.I. 1998.
Scott, E., and Anderson, P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug and Alcohol Review. 1991;10:313-321.
Scotton, B.W.; Chinen, A.B.; and Battista, J.R., eds. 1996.
Selekman, M. "With a little help from my friends": The use of peers in the family therapy of adolescent substance abusers. Family Dynamics of Addiction Quarterly. 1991;1(1):69-76.
Seligman, M.E. 1994.
Seligman, M.E. The effectiveness of psychotherapy: The Consumer Reports study. American Psychologist. 1995;50(12):965-74. [pmid: 8561380].
Selvini-Palazzoli, M.; Boscolo, L.; Cecchin, G.; and Prata, G. 1978.
Shaffer, H., and Burglass, M.E., eds. 1981.
Shedler, J., and Block, J. Adolescent drug use and psychological health: A longitudinal inquiry. American Psychologist. 1990;45(5):612-630. [pmid: 2350080].
Shiffman, S. 1987.
Shiffman, S. Conceptual issues in the study of relapse. In: Gossop, M., ed. Relapse and Addictive Behaviour. 1989;London: Tavistock/Routledge.
Sifneos, P.E. 1972.
Sifneos, P.E. 1987.
Silverman, K.; Chutuape, M.A.; Bigelow, G.E.; and Stitzer, M.L. Voucher-based reinforcement of attendance by unemployed methadone patients in a job skills training program. Drug and Alcohol Dependence. 1996;41(3):197-207. [pmid: 8842632].
Silverman, K.; Higgins, S.T.; Brooner, R.K.; Montoya, I.D.; Cone, E.J.; Schuster, C.R.; and Preston, K.L. Sustained cocaine abstinence in methadone maintenance patients through voucher-based reinforcement therapy. Archives of General Psychiatry. 1996;53:409-415.
Silverman, K.; Wong, C.J.; Umbricht-Schneiter, A.; Montoya, I.D.; Schuster, C.R.; and Preston, K.L. Broad beneficial effects of cocaine abstinence reinforcement among methadone patients. Journal of Consulting and Clinical Psychology. 1998;66(5):811-824. [pmid: 9803700].
Sisson, R.W., and Azrin, N.H. Family-member involvement to initiate and promote treatment of problem drinkers. Journal of Behavior Therapy and Experimental Psychiatry. 1986;17(1):15-21. [pmid: 3700666].
Sisson, R.W., and Azrin, N.H. 1989.
Sisson, R.W., and Azrin, N.H. 1993.
Sitharthan, T.; Kavanagh, D.J.; and Sayer, G. Moderating drinking by correspondence: An evaluation of a new method of intervention. Addiction. 1996;91(3):345-355. [pmid: 8867198].
Sitharthan, T.; Sitharthan, G.; Hough, M.J.; and Kavanagh, D.J. Cue exposure in moderation drinking: A comparison with cognitive-behavior therapy. Journal of Consulting and Clinical Psychology. 1997;65(5):878-882. [pmid: 9337506].
Skinner, B.F. The operant side of behavior therapy. Journal of Behavior Therapy and Experimental Psychiatry. 1988;19(3):171-179. [pmid: 3069874].
Sklar, S.M.; Annis, H.M.; and Turner, N.E. Development and validation of the Drug-Taking Confidence Questionnaire: A measure of coping self-efficacy. Addictive Behaviors. 1997;22(5):655-670. [pmid: 9347068].
Skutle, A., and Berg, G. Training in controlled drinking for early-stage problem drinkers. British Journal of Addiction. 1987;82(5):493-501. [pmid: 3474006].
Smith, C.A.; Haynes, K.N.; Lazarus, R.S.; and Pope, L.K. In search of the "hot" cognitions: Attributions, appraisals, and their relation to emotion. Journal of Personality and Social Psychology. 1993;65(5):916-929. [pmid: 8246115].
Smith, J.E., and Meyers, R.J. 1995.
Smith, J.W., and Frawley, P.J. Treatment outcome of 600 chemically dependent patients treated in a multimodal inpatient program including aversion therapy and pentothal interviews. Journal of Substance Abuse Treatment. 1993;10(4):359-369. [pmid: 8105103].
Smith, J.W.; Frawley, P.J.; and Polissar, N.L. Six- and twelve-month abstinence rates in inpatient alcoholics treated with either faradic aversion or chemical aversion compared with matched inpatients from a treatment registry. Journal of Addictive Diseases. 1997;16(1):5-24. [pmid: 9046442].
Smith, J.W.; Schmeling, G.; and Knowles, P.L. A marijuana smoking cessation clinical trial utilizing THC-free marijuana, aversion therapy, and self-management counseling. Journal of Substance Abuse Treatment. 1988;5(2):89-98. [pmid: 2839683].
Smokowski, P.R., and Wodarski, J.S. 1996.
Smyrinos, K.X., and Kirkby, R.J. Long-term comparison of brief versus unlimited psychodynamic treatments with children and their parent. Journal of Consulting and Clinical Psychology. 1993;61(6):1020-1027. [pmid: 8113479].
Sobell, L.C., and Sobell, M.B. Self-report issues in alcohol abuse: State of the art and future directions. Behavioral Assessment. 1990;12:91-106.
Sobell, L.C.; Sobell, M.B.; and Nirenberg, T.D. Behavioral assessment and treatment planning with alcohol and drug abusers: A review with an emphasis on clinical application. Clinical Psychology Review. 1988;8(1):19-54.
Sobell, L.C.; Toneatto, T.; and Sobell, M.B. Behavioral assessment and treatment planning for alcohol, tobacco, and other drug problems: Current status with an emphasis on clinical applications. Behavior Therapy. 1994;25(4):533-580.
Sobell, M.B.; Maisto, S.; Sobell, L.; Cooper, A.; Cooper, T.; and Sanders, B. 1980.
Solomon, K.E., and Annis, H.M. Outcome and efficacy expectancy in the prediction of post-treatment drinking behaviour. British Journal of Addiction. 1990;85(5):659-665. [pmid: 2354283].
Solomon P. The efficacy of case management services for severely mentally disabled clients. Community Mental Health Journal. 1992;28(3):163-180. [pmid: 1319304].
Soo-Hoo, T. Brief strategic family therapy with Chinese Americans. American Journal of Family Therapy. 1999;27(2):163-179.
Spivak, K.; Sanchez-Craig, M.; and Davila, R. Assisting problem drinkers to change on their own: Effect of specific and non-specific advice. Addiction. 1994;89(9):1135-1142. [pmid: 7987190].
Stanton, M.D. The addict as savior: Heroin, death, and the family. Family Process. 1977;16:191-197.
Stanton, M.D. An integrated structural/strategic approach to family therapy. Journal of Marital and Family Therapy. 1981;7:427-439.
Stanton, M.D., and Heath, A.W. 1997.
Stanton, M.D., and Todd, T.C. 1982.
Stasiewicz, P.R., and Maisto, S.A. Two-factor avoidance theory: The role of negative affect in the maintenance of substance use and substance use disorder. Behavior Therapy. 1993;24(3):337-356.
Steinglass, P.; Davis, D.I.; and Berenson, D. Observations of conjointly hospitalized "alcoholic couples" during sobriety and intoxication: Implications for theory and therapy. Family Process. 1977;16:1-16.
Stephens, R.S.; Curtin, L.; Simpson, E.E.; and Roffman, R.A. Testing the abstinence violation effect construct with marijuana cessation. Addictive Behaviors. 1994;19(1):23-32. [pmid: 8197890].
Stephens, R.S.; Wertz, J.S.; and Roffman, R.A. Predictors of marijuana treatment outcomes: The role of self-efficacy. Journal of Substance Abuse. 1993;5(4):341-354. [pmid: 8186669].
Stitzer, M.; Bigelow, G.; and Liebson, I. 1982.
Stitzer, M.L.; Bigelow, G.E.; Liebson, I.A.; and Hawthorne, J.W. Contingent reinforcement for benzodiazepine-free urines: Evaluation of a drug abuse treatment intervention. Journal of Applied Behavior Analysis. 1982;15(4):493-503. [pmid: 6130059].
Stockwell, T. and Town, C. 1995.
Stout, R.L.; McCrady, B.S.; Longabough, R.; Noel, N.E.; and Beattie, M.C. Marital therapy enhances the long-term effectiveness of alcohol treatment. Alcoholism: Clinical and Experimental Research. 1987;11:213.
Strain, E.C. Psychosocial treatments for cocaine dependence: Rethinking lessons learned. Archives of General Psychiatry. 1999;56(6):503-504. [pmid: 10359462].
Straus, M. Measuring intrafamily conflict and violence: The Conflict Tactics (CT) Scale. Journal of Marriage and the Family. 1979;41:75-88.
Strean, H.S. 1994.
Strupp, H.H., and Hadley, S.W. Specific versus non-specific factors in psychotherapy: A controlled study of outcome. Archives of General Psychiatry. 1979;36(10):1125-1136. [pmid: 475546].
Strupp, H.H. Success and failure in time-limited psychotherapy. Archives of General Psychiatry. 1980;37(8):947-954. [pmid: 7406658].
Strupp, H.H., and Binder, J.L. 1984.
Sue, D.W., and Sue, D. 1990.
Szapocznik, J., and Kurtines, W.M. 1989.
Szapocznik, J.; Perez-Vidal, A.; Brickman, A.L.; Foote, F.H.; Santisteban, D.; Herris, O.; and Kurtines, W.M. Engaging adolescent drug abusers and their families in treatment: A strategic structural systems approach. Journal of Consulting and Clinical Psychology. 1988;56(4):552-557. [pmid: 3198813].
Szapocznik, J.; Rio, A.; and Kurtines, W. 1991.
Szapocznik, J.; Santisteban, D.; Rio, A.; and Perez-Vidal, A. Family effectiveness training: An intervention to prevent drug abuse and problem behaviors in Hispanic adolescents. Hispanic Journal of Behavioral Sciences. 1989;11(1): 4-27.
Thomas, E.J., and Ager, R.D. 1993.
Thomas, E.J.; Yoshioka, M.R.; and Ager, R.D. 1994.
Todd, T.C. 1986.
Tucker, J.A.; Vuchinich, R.E.; and Downey, K.K. 1981.
Turner, F.J., ed. 1976.
van Bilsen, H., and Whitehead, B. Learning controlled drug use: A case study. Behavioural and Cognitive Psychotherapy. 1994;22(1):87-95.
Van De Riet, V.; Korb, M.P.; and Gorrell, J.J. 1980.
Van Utt, G., and Burglass, M.E. 1978.
Velicer, W.F.; Prochaska, J.O.; Rossi, J.S.; and Snow, M.G. Assessing outcome in smoking cessation studies. Psychological Bulletin. 1992;111(1):23-41. [pmid: 1539088].
Volpicelli, J.R.; Alterman, A.I.; Hayashida, M.; and O'Brien, C.P. Naltrexone in the treatment of alcohol dependence. Archives of General Psychiatry. 1992;49(11):876-880. [pmid: 1345133].
Von Eckartsberg, R. 1983.
Wallace, P.; Cutler, S.; and Haines, A. Randomised controlled trial of general intervention in patients with excessive alcohol consumption. British Medical Journal. 1988;297:663-668.
Walton, M.A.; Castro, F.G.; and Barrington, E.H. The role of attributions in abstinence, lapse, and relapse following substance abuse treatment. Addictive Behaviors. 1994;19(3):319-331. [pmid: 7942249].
Watzlawick, P.; Bavelas, J.B.; and Jackson, D.D. 1967.
Watzlawick, P.; Weakland, J.; and Fisch, R. 1974.
Weeks, G.R., and L'Abate, L. A compilation of paradoxical methods. American Journal of Family Therapy. 1979;7:61-76.
Wegscheider-Cruse, S. 1989.
Weil, A. 1972.
Weil, A., and Rosen, W. 1993.
Weitz, R. Feminist consciousness raising, self-concept, and depression. Sex Roles. 1982;8:213-241.
Wetchler, J.L.; McCollum, E.E.; Nelson, T.S.; Trepper, T.S.; and Lewis, R.A. 1993.
Whalen, T. Wives of alcoholics: Four types observed in a family service agency. Quarterly Journal of Studies on Alcohol. 1953;14:632-641.
Wilber, K. 1995.
Wilk, A.I.; Jensen, N.M.; and Havighurst, T.C. Meta-analysis of randomized control trials addressing brief interventions in heavy alcohol drinkers. Journal of General Internal Medicine. 1997;12(5):274-283. [pmid: 9159696].
Wills, T.A., and Hirky, A.E. 1996.
Winn, M.E. Drawing upon the strengths of couples in the treatment of chronic drug addiction. Journal of Family Psychotherapy. 1995;6(3):33-54.
Wittine, B. 1989.
Wolberg, L.R. 1980.
Wolman, B., ed. 1977.
Woody, G.E.; Luborsky, L.; McLellan, A.T.; and O'Brien, C.P. 1985.
Woody, G.E.; Luborsky, L.; McLellan, A.T.; O'Brien, C.P.; Beck, A.T.; Blaine, J.; Herman, I.; and Hole, A. Psychotherapy for opiate addicts: Does it help?. Archives of General Psychiatry. 1983;40:639-645.
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. Twelve-month follow-up of psychotherapy for opiate dependence. American Journal of Psychiatry. 1987;144(5):590-596. [pmid: 3578568].
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. 1990.
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. Psychotherapy in community methadone programs: A validation study. American Journal of Psychiatry. 1995;152(9):1302-1308. [pmid: 7653685].
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. Psychotherapy with opioid-dependent patients. Psychiatric Times. 1998;15(11).
Woody G.E.; Mercer D.; and Luborsky L. 1994.
Wright, J.H., and Beck, A. 1994.
Yalom, I.D. 1980.
Yalom, I.D. 1995.
Yalom, I.D. 1997.
Zients, A. 1993.
Ziter, M.L.P. Culturally sensitive treatment of Black alcoholic families. Social Work. 1987;32(2):130-135.
Zitter, R., and McCrady, B.S. 1993.
Zweben, A.; Pearlman, S.; and Li, S. A comparison of brief advice and conjoint therapy in the treatment of alcohol abuse: The results of the Marital Systems Study. British Journal of Addiction. 1988;83(8):899-916. [pmid: 3167248].
Zweben, J.E. Recovery-oriented psychotherapy: Patient resistances and therapist dilemmas. Journal of Substance Abuse Treatment. 1989;6(2):123-132. [pmid: 2746711].