# Appendices

Appendix A --Bibliography

Appendix B—Information and Training Resources

Appendix C - Glossary

Appendix D—Health Promotion Workbook

Appendix E—Resource Panel

Appendix F—Field Reviewers