# Consensus Panel

Chair
- Kristen Lawton Barry, Ph.D.
- Associate Research Scientist
- Alcohol Research Center
- University of Michigan
- Ann Arbor, Michigan

Workgroup Leaders
- Christopher W. Dunn, Ph.D., M.A.C., C.D.C.
- Psychiatry and Behavioral Science
- University of Washington
- Seattle, Washington
- Jerry P. Flanzer, D.S.W., L.C.S.W., C.A.C.
- Director
- Recovery and Family Treatment, Inc.
- Alexandria, Virginia
- Stephen Gedo, Ph.D.
- Clinical Psychologist
- Gaffney, South Carolina
- Eugene Herrington, Ph.D.
- Associate Professor
- Department of Counseling and Psychological Services
- Clark Atlanta University
- Atlanta, Georgia
- Fredrick Rotgers, Psy.D.
- Director
- Program for Addictions Consultation and Treatment
- Center of Alcohol Studies
- Rutgers University
- New Brunswick, New Jersey
- Terry Soo-Hoo, Ph.D.
- Clinic Director/Assistant Professor
- Counseling Psychology Department
- University of San Francisco
- San Francisco, California

Panelists
- Janice S. Bennett, M.S., C.S.A.C.
- Owner/Consultant
- Pacific Consulting and Training Services of Hawaii
- Honolulu, Hawaii
- Robert L. Chapman, M.S.S.W., C.A.D.O.A.C., C.R.P.S.
- Cumberland Heights
- Nashville, Tennessee
- John W. Herdman, Ph.D., C.A.D.A.C.
- Psychologist
- The Encouragement Place
- Lincoln, Nebraska
- Fanny G. Nicholson, C.C.S.W., A.C.S.W., N.C.A.C.I., C.S.A.E.
- Alcohol and Drug Specialist
- Oconaluftee Job Corps
- Cherokee, North Carolina
- Mary Alice Orito, C.S.W., C.A.S.A.C., N.C.A.C.I.
- Evaluation Supervisor
- Stuyvesant Square Outpatient Services for Chemical Dependency
- New York, New York
- Jerome J. Platt, Ph.D.
- Professor of Psychiatry and Public Health
- Director, Institute for Addictive Disorders
- Hahnemann School of Medicine
- Allegheny University of the Health Sciences
- Philadelphia, Pennsylvania
- Marilyn Sawyer Sommers, Ph.D., R.N.
- Professor
- College of Nursing
- University of Cincinnati
- Cincinnati, Ohio
- José Luis Soria, M.A., L.C.D.C., I.C.A.D.C., C.C.G.C., C.A.D.A.C.
- Clinical Deputy Director
- Aliviane NO-AD, Inc.
- El Paso, Texas
- Ava H. Stanley, M.D.
- Somerset, New Jersey
- Robert S. Stephens, Ph.D.
- Associate Professor
- Department of Psychology
- Virginia Polytechnic Institute and State University
- Blacksburg, Virginia