# Consensus Panel

Chair
- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center and Matrix Institute on Addiction
- Deputy Director, UCLA Addiction Medicine Services
- Los Angeles, California

Workgroup Leaders
- Felipe G. Castro, M.S.W., Ph.D.
- Professor
- Hispanic Research Center
- Department of Psychology
- Arizona State University
- Tempe, Arizona
- James W. Cornish, M.D.
- Assistant Professor of Psychiatry
- Director, Division of Pharmacotherapy
- Treatment Research Center
- University of Pennsylvania
- Department of Veterans Affairs Medical Center
- Philadelphia, Pennsylvania
- Frances R. Levin, M.D.
- Assistant Professor
- Clinical and Educational Activities
- Division on Substance Abuse
- Columbia University
- New York, New York
- Michael J. McCann, M.A.
- Research Coordinator
- Matrix Center
- Los Angeles, California

Panelists
- Arlene Hall, R.N., M.S., C.D.
- Director of Nursing
- Hope House
- Crownsville, Maryland
- Stephen Higgins, Ph.D.
- Professor
- Departments of Psychiatry and Psychology
- Ira Allen School
- University of Vermont
- Burlington, Vermont
- Kyle M. Kampman, M.D.
- Assistant Professor of Psychiatry
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Quintin Kingfisher
- Medical Resources
- Tribal Health
- Lame Deer, Montana
- Judy Knobbe, M.S.W., L.I.S.W., C.A.D.C.
- Director
- Heart of Iowa
- Area Substance Abuse Council
- Cedar Rapids, Iowa
- Wendy Lay
- Program Specialist
- Bureau of Alcohol and Drug Abuse
- State of Nevada
- Carson City, Nevada
- Scott M. Reiner, M.S., C.A.C., C.C.S.
- Substance Abuse Program Supervisor
- Substance Abuse Services Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia
- Ewa Szumotalska Stamper, Ph.D.
- Police Psychologist
- Honolulu Police Department
- Private Practice in Clinical and Addictions Psychology
- Honolulu, Hawaii
- Arnold M. Washton, Ph.D.
- Private Practice of Addiction Psychology
- Parkland, Florida
- Dennis A. Weis, M.D.
- Medical Director
- Powell Center for Disease Control
- Iowa Lutheran Hospital
- President
- American Society of Addiction Medicine
- Iowa Chapter
- Des Moines, Iowa