# Appendix F --Field Reviewers

- Patricia Bradford, L.I.S.W., L.M.F.T., C.T.S.
- P.A. Bradford and Associates
- Columbia, South Carolina

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Carol L. DeRosa, R.N.
- Registered Nurse Consultant
- Child Advocacy Unit
- Anne Arundel County Department of Social Services
- Severna Park, Maryland

- Karen Kelly-Woodall, M.S., M.A.C., N.C.A.C. II
- Criminal Justice Coordinator
- Cork Institute
- Georgia Addiction Technology Transfer Center
- Morehouse School of Medicine
- Atlanta, Georgia

- Mitchell Markinem, M.A., N.C.A.C. II
- Drug Court Program Coordinator
- Fifth Circuit Solictor's Office
- Columbia, South Carolina

- Bonnie I. Pipe, B.S., C.C.D.C.
- Clinical Director
- Northern Cheyenne Recovery Center
- Northern Cheyenne Board of Health
- Lame Deer, Montana

- Lynda A. Price, Ph.D., I.C.A.D.C.
- Treatment Coordinator
- Global House
- National Drug Commission
- Hamilton, Bermuda

- Margaret M. Salinger, M.S.N., R.N., C.A.R.N.
- National Nurses Society on Addiction
- Department of Veterans Affairs Medical Center
- Coatesville, Pennsylvania

- Richard E. Steinberg, M.S.
- President
- WestCare
- Las Vegas, Nevada

- Christopher J. Stock, Pharm.D.
- Clinical Pharmacist
- Substance Abuse Program
- Veterans Medical Center
- Salt Lake City, Utah

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabiliation
- Department of Veterans Affairs
- Mental Health and Behavioral Sciences Services
- Washington, DC

- Sushma Taylor, Ph.D.
- Executive Director
- Administrative Office
- Center Point, Inc.
- San Rafael, California

- Elizabeth Wells, Ph.D.
- Research Associate Professor
- Department of Psychiatry and Behavioral Sciences
- University of Washington
- Seattle, Washington