# Appendix E --Resource Panel

- Patrick Carpenter
- Policy Analyst
- Executive Office of the President
- Office of National Drug Control Policy
- Washington, D.C.

- Johanna Clevenger, M.D.
- Chief
- Alcoholism and Substance Abuse Program Branch
- Indian Health Service
- Rockville, Maryland

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Jerome Jaffe, M.D.
- Director
- Office of Evaluation, Scientific Analysis and Synthesis
- Center for Substance Abuse Treatment
- Rockville, Maryland

- George Kanuck
- Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Kate Malliarakis, C.N.P., M.S.M., N.C.A.D.C. II
- Executive Office of the President
- Office for Demand Reduction
- Office of National Drug Control Policy
- Washington, D.C.

- Eleanor Sargent, C.A.C., N.C.A.C., M.A.
- Director
- Clinical Issues
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia