# Appendix D—Glossary

Addiction: : A chronic, relapsing disease, characterized by compulsive drug-seeking and drug use, and by neurological adaptations in the brain.

Amygdala: : A discrete brain area that is part of the limbic system, has a large number of dopamine-containing neurons, and plays a role in the learning and performing of certain behaviors in response to incentive stimuli (i.e., motivation, reinforcement).

Analog: : A chemical compound that is similar to another drug in its effects, but differs slightly in its chemical structure.

Anergia: : Lack of energy.

Anhedonia: : Loss of interest in pleasurable activities; the inability to feel pleasure.

Anorexia: : Loss of appetite, accompanied by weight loss and thin, gaunt appearance.

Arrhythmia: : Irregular heartbeat.

Axon: : A long, thin fiber that conducts electrical impulses away from the neuron's cell body and on to other neurons.

Benzodiazepines: : Drugs that relieve anxiety or are prescribed as sedatives; they are among the most widely prescribed medications and include valium and librium.

Bradycardia: : Slowed heartbeat.

Bruxism: : The habitual, involuntary grinding of teeth, usually during sleep.

Cachexia: : Weight loss, wasting of muscle, and debility.

Central nervous system (CNS): : The brain and spinal cord.

Cerebellum: : A brain structure that controls coordination and regulation of complex voluntary muscular movements, posture, and balance.

Choreoathetoid: : Involuntary movement.

Convulsion: : An abnormal, uncontrollably violent involuntary contraction or series of contractions of the muscles; spasm or series of jerkings of the face, trunk, or limbs.

Craving: : A powerful, often uncontrollable desire for drugs.

Dendrites: : Thin, branched extensions of a neuron that extend from the cell in branched tendrils to receive information from adjacent neurons; they conduct electrical impulses inward toward the cell body.

Dermatitis: : Inflammation of the skin.

Designer drug: : A synthetic analog of a restricted drug that has psychoactive properties.

Detoxification: : A process of allowing the body to rid itself of a drug while managing the symptoms of withdrawal; often the first step in a drug treatment program.

Diaphoresis: : Profuse sweating, often with chills.

Diastolic blood pressure: : The pressure exerted by the blood on the cavities of the heart at the moment when they fill with blood.

Dopamine: : A neurotransmitter present in several brain regions involved in movement, emotion, motivation, reinforcement, and feelings of pleasure.

Dopaminergic: : Dopamine-mediated.

Dysphoria: : A mood of general dissatisfaction, restlessness, and anxiety.

Glucose utilization: : A general indicator of physiological activity; in the brain, an indicator of neurological activity presumed to be information processing.

Hypertension: : Elevated blood pressure.

Hyperthermia: : Elevated body temperature.

Limbic system: : A group of subcortical brain structures that are especially concerned with emotion and motivation.

Narcolepsy: : A disorder characterized by uncontrollable attacks of deep sleep.

Neuron: : The morphological and functional unit of the nervous system, consisting of the cell body, dendrites, and axon.

Neurotransmitters: : Chemical substances that transmit signals between neurons and that modulate neuronal activity.

Nucleus accumbens: : A discrete brain area that is part of the limbic system, has a large number of dopamine-containing neurons, and plays a role in the learning and performing of certain behaviors in response to incentive stimuli (i.e., motivation and reinforcement).

Paranoia: : A mental disorder characterized by the presence of systematized delusions, often of a persecutory character, involving being followed, poisoned, or harmed by other means, in an otherwise intact personality.

Physical dependence: : An adaptive physiological state that occurs with regular drug use and results in a withdrawal syndrome when drug use stops.

Psychosis: : A mental and behavioral disorder characterized by symptoms such as delusions or hallucinations that indicate an impaired conception of reality.

Psychosocial intervention: : An individual or group interaction that examines both psychological and social aspects of a person's life (e.g., age, education, marital, and related aspects of a person's life history).

Rhabdomyolysis: : An acute, potentially fatal disease of skeletal muscle characterized by muscle pain, weakness, and the production of red-brown urine.

Rush: : A surge of euphoric pleasure that rapidly follows administration of a drug.

Seizure: : Manifestation of a sudden onset of an abnormal mental or physical state, often characterized by complex behaviors, impaired consciousness, and convulsions.

Serotonin: : A neurotransmitter that has been implicated in states of consciousness, mood, depression, and anxiety.

Serotonergic: : Serotonin-mediated.

Stereotyped behaviors: : Frequent, almost mechanical repetition of the same posture, meaningless gestures or movement, or form of speech (as in schizophrenia).

Substantia nigra: : A discrete brain area that is part of the nigrostriatal system, interacts with the limbic system, has a large number of dopamine-containing cells, and is involved in learning to automatically execute complex movements triggered by a voluntary command; degenerative impairments in this area cause motor disturbances that occur in Parkinson's disease.

Synapse: : A microscopic gap, cleft, or junction between neurons across which chemical signals (neurotransmitters) are transmitted.

Systolic blood pressure. : The pressure exerted by the blood on the cavities of the heart at the moment when they contract.

Tachycardia: : Rapid heartbeat, with or without arrhythmia and chest pain.

Tolerance: : A condition in which higher doses of a drug are required to produce the same effect as experienced initially; often leads to physical dependence.

Toxic: : Temporary or permanent drug effects that are detrimental to the function or structure of a cell, organ, or organ system.

Urticaria: : An eruption of itching wheals, usually of systemic origin, which may be due to a state of hypersensitivity to food, drugs, or physical agents, such as heat or cold.

Ventral tegmental area: : A discrete brain area that is part of the mesocortical system, interacts with the limbic system, has a large number of dopamine-containing neurons, and is involved in attention span and short-term memory.

Withdrawal: : A psychological and/or physical syndrome caused by the abrupt cessation of the use of a drug in an habituated individual.