# Appendix C --Screening Tests for Cognitive Impairments

The following list provides a number of tests that can be used to screen for cognitive impairments in stimulant users. The first two can generally be administered by counselors who are culturally competent for their client population. The other six tests should be administered and interpreted by a psychological testing specialist.

These tests can be administered quickly and easily and are used extensively in batteries created by neuro- and cognitive psychologists. Although the tests are very sensitive in revealing the existence of cognitive problems, particularly when several of the tests are administered in combination, they do not provide information on the exact nature or depth of the impairment. Positive screens should be referred to an appropriate collaborator (e.g., a neuropsychologist) for more extensive assessments.

## Cognistat (Neurobehavioral Cognitive Status Examination)

This test is designed to assess intellectual functioning in five areas in adults 18 years of age and older. Administration of the test takes about 10 minutes for cognitively intact individuals and from 20 to 30 minutes for those who are cognitively impaired. Cognistat is available from:

Psychological Assessment Resources, Inc. P.O. Box 998 Odessa, FL 33556 1-800-331-TEST

## Brief Neuropsychological Cognitive Examination (BNCE)

This test is designed to evaluate the cognitive status of clients with psychiatric disorders or psychiatric manifestations of neurological disease. The reading level required for the test is minimal, and it is recommended for assessing mood disorders and substance use disorders. Both adolescents and adults can be tested in about 30 minutes. The BNCE is available from:

Western Psychological Services 12031 Wilshire Boulevard Los Angeles, CA 90025-1251 1-800-648-8857

## Backward Digital Span

This test is simply saying numbers at the rate of one per second and asking the client to repeat them backwards. For example, you might say "3, 8, 6" and would expect a response of "6, 8, 3." The examiner starts with three digits and goes up to nine digits. Three different number strings are presented at each level. If the client misses all three at a particular level, then the test is stopped. This test takes about 5 minutes to administer. It is a test of working memory capacity.

## FAS Test of Verbal Fluency

The client is asked to say as many words (excluding proper names) that start with the letter F as she can in 1 minute. This is then repeated with the letter A, and again with the letter S.

## Digit Symbol Subtest of the WAIS-R

This test taps the same thing as the Symbol Digit Modalities Test (i.e., the ability to manipulate simple information and pay attention). It is part of the revised Wechsler Adult Intelligence Scale (WAIS-R) and can be obtained from:

The Psychological Corporation Harcourt Brace & Co. 15 East 26th Street 15th Floor New York, NY 10010-1505 1-800-211-8378

## Trail Making Test, Parts A and B

This test is very sensitive to brain function, is essentially connecting the dots, and takes about 5 minutes for both parts. The citation for the test is as follows:

Reitan, R.M. Validity of the trail making test as an indication of organic brain damage. Perceptual and Motor Skills 8:271-276, 1958.

## Stroop Color Word Interference Test

Many versions of this test exist. It taps selective attention and the ability to ignore irrelevant information. A version can be obtained from either of the testing companies listed above.

## Shipley-Hartford Tests of Vocabulary And Abstract Thinking

This is a short-form IQ test that takes a maximum of 20 minutes to administer. It is old but still widely used--particularly in the aging literature. The citation for the test is as follows:

Shipley, W.C. A self-administering scale for measuring intellectual impairment and deterioration. Journal of Psychology 9:371-377, 1940.

## Repeated Memory Test (RMT)

The RMT, which was developed by Sara L. Simon, Ph.D., has five different versions, each equivalent in word frequency and length. Because the test is so simple, giving it multiple times does not seem to involve a learning curve. Each test consists of 25 words each printed 3/4 inches high on a 3-inch x 5-inch card.

The client is first told that she will be shown some words and that she will be asked to remember them. Then the words are presented to the subject, one at a time for 1 second each. When the client has seen all of the cards, there is an approximately 10-minute interval filled with distracter tasks. During this interval, other tests--such as the Digit Symbol, Trail Making A, and Trail Making B tests--may be administered.

The client is then given the recall test and told to write down any words that she remembers. The client is allowed as much time as she needs to complete the test. However, if 2 minutes have gone by without the client responding, suggest that she stop because no one remembers them all.

Next the client is given the recognition test and asked to circle the words that she remembers being shown.

A copy of the test follows, but for further information on the RMT, contact

Sara L. Simon, Ph.D. Los Angeles Addiction Treatment Consortium 1001 W. Carson St., Suite U. Torrance, CA 90502 310-224-4670 310-782-9140 (fax)

### Scoring:

The recall test has two measures.

1. Number correct
2. Number of false positives (items remembered but not shown)

The recognition test has two measures.

1. Number correct
2. Number of false positives (items remembered but not shown)

A large number of false positives suggests that the patient was guessing and probably is having memory problems.

Test 1 Words

SAW | SALTSHAKER
OWL | ANCHOR
TIE | MONKEY
CAP | CANNON
KITE | SWEATER
NAIL | BICYCLE
PLUG | OSTRICH
DEER | THIMBLE
CHAIR | AIRPLANE
TRAIN | CIGARETTE
STOVE | WATERMELON
CIGAR | GARBAGE CAN
GLOVE

Recognition Test 1

Circle any items that were shown to you today during the testing session.
BASEBALL BAT | FOOTBALL | OSTRICH
CLOWN | MITTEN | SALTSHAKER
DESK | BICYCLE | RUG
BROOM | WATERMELON | CHICKEN
CHAIR | OWL | ROOSTER
BUS | DEER | GLOVE
TRAIN | PIPE | ANCHOR
WINDOW | SWEATER | GRAPES
SAW | BELT | STOVE
ENVELOPE | NAIL | IRON
KITE | CANNON | MONKEY
THIMBLE | GARBAGE CAN | CIGAR
TREE | GRASSHOPPER | AIRPLANE
MOON | KANGAROO | TIE
LEG | BREAD | CIGARETTE
PLUG | COAT | CAP
CLOCK | MUSHROOM | COW

Test 2 Words

RING | CHURCH
ANT | BEETLE
CAT | BLOUSE
POT | WRENCH
CARROT | PEPPER
CORN | GORILLA
STAR | PEACOCK
LION | UMBRELLA
LAMP | SUITCASE
BEAR | ACCORDION
PEACH | TENNIS RACKET
COUCH | CLOTHESPIN
CHAIN

Recognition Test 2

Circle any items that were shown to you today during the testing session.
ACCORDION | PEACH | TOOTHBRUSH
BEETLE | PEPPER | CARROT
JACKET | EAGLE | LETTUCE
HANGER | CAMEL | BEAR
RACCOON | WRENCH | PLIERS
ROLLING PIN | POT | RABBIT
TENNIS RACKET | FENCE | CHAIN
GORILLA | ARM | PEACOCK
UMBRELLA | SKIRT | SAILBOAT
MOTORCYCLE | CAR | LAMP
CUP | ANT | GIRAFFE
SWING | SUITCASE | TELEPHONE
FOOT | LION | FOX
CORN | CLOTHESPIN | BLOUSE
CAT | LEAF | CHURCH
STAR | SOCK | RING
DRESSER | CONCH | SHOE

Test 3 Words

TOP | WATCH
PIG | PENCIL
EAR | BARREL
LIPS | BASKET
REFRIGERATOR | DONKEY
FISH | TRUMPET
PAINTBRUSH | PENGUIN
SHOE | CHISEL
SWAN | SCISSORS
HORSE | SNOWMAN
RULER | ALLIGATOR
CROWN | ARTICHOKE
ONION

Recognition Test 3

Circle any items that were shown to you today during the testing session.
DOORKNOB | REFRIGERATOR | ALLIGATOR
TOMATO | BARN | ARTICHOKE
WATCH | CELERY | HELICOPTER
CHISEL | PANTS | PENGUIN
POTATO | TRUMPET | TABLE
KETTLE | SHEEP | SCISSORS
ASPARAGUS | PENCIL | SNOWMAN
FINGER | HORSE | WINDMILL
SLED | HAT | SHOE
CROWN | LOBSTER | BARREL
SWAN | WINEGLASS | DONKEY
POCKETBOOK | NUT | BASKET
BALL | RULER | DOG
KEY | FORK | PAINTBRUSH
DOLL | PEANUT | LIPS
PIG | EAR | ONION
TOP | FISH | BOAT

Test 4 Words

BED | PIANO
TOE | BOTTLE
COW | GUITAR
BOOK | SPIDER
GOAT | LEOPARD
WHEEL | PITCHER
BELL | BALLOON
FLAG | SEA HORSE
DRESS | RHINOCEROS
STOOL | BUTTERFLY
SNAIL | LIGHT SWITCH
MOUSE | TOASTER
THUMB

Recognition Test 4

Circle any items that were shown to you today during the testing session.
PITCHER | LIGHT SWITCH | TOE
BUTTERFLY | VIOLIN | GUITAR
LADDER | ASHTRAY | CAKE
PUMPKIN | SNAIL | BOWL
SCREWDRIVER | SEA HORSE | CANDLE
APPLE | BOOK | HAMMER
BOTTLE | IRONING BOARD | THUMB
TOASTER | DRESS | ROLLERSKATE
BANANA | FLAG | AXE
SPOON | LIGHTBULB | BALLOON
LEOPARD | KNIFE | PIANO
SPIDER | HEART | RHINOCEROS
HAIR | MOUSE | BIRD
WHEEL | BOW | TIGER
STOOL | SHIRT | BED
SUN | BELL | GOAT

Test 5 Words

EYE | WAGON
BEE | COMB
FLY | CHERRY
GUN | ORANGE
HARP | FLOWER
DUCK | WHISTLE
LOCK | FRYING PAN
LEMON | SANDWICH
BRUSH | NECKLACE
BUTTON | PINEAPPLE
ARROW | TELEVISION
SCREW | CATERPILLAR
GLASS

REcognition Test 5

Circle any items that were shown to you today during the testing session.
COMB | NAIL FILE | PINEAPPLE
ORANGE | EYE | TURTLE
SANDWICH | MOUNTAIN | WHISTLE
FROG | WAGON | SCREW
TELEVISION | HARP | BOOT
GLASS | PEN | TRAFFIC LIGHT
CHERRY | CATERPILLAR | GLASSES
FLOWER | NEEDLE | NOSE
ROCKING CHAIR | SNAKE | SQUIRREL
TRUCK | BUTTON | STRAWBERRY
LEMON | FRYING PAN | PEAR
BEE | VEST | FLUTE
SKUNK | GUN | BRUSH
SEAL | ELEPHANT | DUCK
CLOUD | FLY | BOX
NECKLACE | ARROW | LOCK
DOOR | VASE | SOFA

Name __________________________________________ Date ___________________

Recall Test for Words

Please write down all of the test words that you remember below: