# Appendix A—Bibliography

Alberti, R.E., and Emmons, M.L. Your Perfect Right: A Guide to Assertive Living. San Luis Obsipo, CA: Impact Press, 1982.
Allcott, J.V., III; Barnhart, R.A.; and Mooney, L.A. Acute lead poisoning in two users of illicit methamphetamine. . Journal of the American Medical Association. 1987;258:510-511.
Amass, L. Financing voucher programs for pregnant substance abusers through community donations [abstract]. In: Harris, L.S., ed. Problems of Drug Dependence 1996: Proceedings of the 58th Annual Scientific Meeting of the College on Problems of Drug Dependence. NIDA Research Monograph Series, Number 174. DHHS Pub. No. (ADM) 97-4236. Rockville, MD: National Institute on Drug Abuse, 1997. p. 60.
American Medical Association. International Classification of Diseases, 9th revision clinical modification (ICD-9-CM). Chicago: American Medical Association, 1997.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. Washington, DC: American Psychiatric Association, 1994.
Anglin, D.; Spears, K.L.; and Hutson, H.R. Flunitrazepam and its involvement in date or acquaintance rape. Academic Emergency Medicine. 1997;4(4):323-326. [pmid: 9107334].
Anglin, M.D.; Kalechstein, A.; Magline, M.; Annon, J.; and Fiorentine, R. (UCLA Drug Abuse Research Center). Epidemiology and Treatment of Methamphetamine Abuse in California: A Regional Report. Rockville, MD: National Evaluation Data and Technical Assistance Center (NEDTAC), Center for Substance Abuse Treatment, April 1998.
Angrist, B. Amphetamine psychosis: Clinical variations of the syndrome. In: Cho, A.K., and Segal, D.S., eds. Amphetamine and Its Analogs: Psychopharmacology, Toxicology, and Abuse. San Diego, CA: Academic Press, 1994.
Anker, A.L., and Crowley, T.J. Use of contingency contracts in specialty clinics for cocaine abuse. In: Harris, L.S., ed. Problems of Drug Dependence, 1981: Proceedings of the 43rd Annual Scientific Meeting, the Committee on Problems of Drug Dependence. NIDA Research Monograph Series, Number 41. NTIS Pub. No. 82-190760. Rockville, MD: National Institute on Drug Abuse, 1982. pp. 452-459.
Anthony, J.C.; Vlahov, D.; Nelson, K.E.; Cohn, S.; Astemborski, J.; and Solomon, L. New evidence on intravenous cocaine use and the risk of infection with human immunodeficiency virus type 1. American Journal of Epidemiology. 1991;134(10):1175-1189. [pmid: 1746528].
Azrin, N.H., and Besalel, V.A. Job Club Counselor's Manual. Baltimore, MD: University Park Press, 1980.
Azrin, N.H.; Naster, B.J.; and Jones, R. Reciprocity counseling: A rapid learning based procedure for marital counseling. Behavioral Research and Therapy. 1973;11:365-382.
Barry, C.T. "Treatment for methamphetamine abuse disorders." Presented at the Methamphetamine Interagency Task Force Federal Advisory Committee Meeting, Washington, DC, May 4-5. 1998.
Bauer, L.O. Psychomotor and electroencephalographic sequelae of cocaine dependence. In: Majewska, M.D., ed. Neurotoxicity and Neuropathology Associated With Cocaine Abuse. NIDA Research Monograph Series, Number 163. DHHS Pub. No. (ADM) 96-4019. Rockville, MD: National Institute on Drug Abuse, 1996. pp. 66-93.
Beebe, D.K., and Walley, E.J. Smokable methamphetamine (ICE): An old drug in a different form. American Family Physician. 1995;51:449-453.
Bell, D.S. The experimental reproduction of amphetamine psychosis. Archives of General Psychiatry. 1973;29(1):35-40. [pmid: 4711131].
Biederman, J.; Faraone, S.V.; Spencer, T.; Wilens, T.; Norman, D.; Lapey, K.A.; Mick, E.; Lehman, B.K.; and Doyle, A. Patterns of psychiatric comorbidity, cognition, and psychosocial functioning in adults with attention deficit hyperactivity disorder. American Journal of Psychiatry. 1993;150(12):1792-1798. [pmid: 8238632].
Biederman, J.; Wilens, T.; Mick, E.; Milberger, S.; Spencer, T.J.; and Faraone, S.V. Psychoactive substance use disorders in adults with attention deficit hyperactivity disorder (ADHD): Effects of ADHD and psychiatric comorbidity. American Journal of Psychiatry. 1995;152(11):1652-1658. [pmid: 7485630].
Bigelow, G.E.; Stitzer, M.L.; Griffiths, R.R.; and Liebson, I.A. Contingency management approaches to drug self-administration and drug abuse: Efficacy and limitations. Addictive Behavior. 1981;6:241-252.
Brady, K.T.; Lydiard, R.B.; Malcolm, R.; and Ballenger, J.C. Cocaine-induced psychosis. Journal of Clinical Psychiatry. 1991;52(12):509-512. [pmid: 1752853].
Brotman, A.; Witkie, S.M.; Gelenberg, A.J.; Falk, W.E.; Wojcik, J.; and Leahy, L. An open trial of maprotiline for the treatment of cocaine abuse: A pilot study. Journal of Clinical Psychopharmacology. 1988;8:125-127.
Budney, A.J., and Higgins, S.T. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. Therapy Manuals for Drug Addiction, Manual 2. DHHS Pub. No. (ADM) 98-4309. Rockville, MD: National Institute on Drug Abuse, 1998.
Burton, B.T. Heavy metal and organic contaminants associated with illicit methamphetamine production. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 47-59.
Carroll, K.M. "Combining psychotherapy and pharmacotherapy treatments to improve drug abuse outcomes." Paper presented at Addictions '96: Treatments Across the Addictions, International Symposium, Hilton Head, SC, September 27-29. 1996.
Carroll, K.M.; Chang, G.; Behr, H.; Clinton, B.; and Kosten, T. Improving treatment outcome in pregnant, methadone-maintained women: Results from a randomized clinical trial. American Journal on Addiction. 1995a;4:56-59.
Carroll, K.M.; Nich, C.; and Rounsaville, B.J. Differential symptom reduction in depressed cocaine abusers treated with psychotherapy and pharmacotherapy. Journal of Nervous and Mental Disease. 1995b;183(4):251-259. [pmid: 7714514].
Carroll, K.M.; Power, M.E.; Bryant, K.; and Rounsaville, B.J. One year follow-up status of treatment seeking cocaine abusers. Psychopathology and dependence severity as predictors of outcome. Journal of Nervous and Mental Disease. 1993a;181:71-79.
Carroll, K.M.; Rounsaville, B.J.; and Gawin, F.H. A comparative trial of psychotherapies for ambulatory cocaine abusers: Relapse prevention and interpersonal psychotherapy. American Journal of Drug and Alcohol Abuse. 1991a;17:229-247.
Carroll, K.M.; Rounsaville, B.J.; Gordon, L.T.; Nich, C.; Jatlow, P.; Bisighini, R.M.; and Gawin, F.H. Psychotherapy and pharmacotherapy for ambulatory cocaine abusers. Archives of General Psychiatry. 1994a;51:177-187.
Carroll, K.M.; Rounsaville, B.J.; and Keller, D.S. Relapse prevention strategies for the treatment of cocaine abusers. American Journal of Drug and Alcohol Abuse. 1991b;17:249-265.
Carroll, K.M.; Rounsaville, B.J.; Nich C.; Gordon, L.; and Gawin F. Integrating psychotherapy and pharmacotherapy for cocaine dependence: Results from a randomized clinical trial. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Integrating Behavioral Therapies With Medications in the Treatment of Drug Dependence. NIDA Research Monograph Series, Number 150. DHHS Pub. No. (ADM) 95-3899. Rockville, MD: National Institute on Drug Abuse, 1995c. pp. 19-36.
Carroll, K.M.; Rounsaville, B.J.; Nich, C.; Gordon, L.T.; Wirtz, P.W.; and Gawin, F. One-year followup of psychotherapy and pharmacotherapy for cocaine dependence. Archives of General Psychiatry. 1994b;51: 989-997.
Carroll, K.; Ziedonis, D.; O'Malley, S.; McCance-Katz, E.; Gordon, L.; and Rounsaville, B. Pharmacologic interventions for alcohol- and cocaine-abusing individuals: A pilot study of disulfiram vs. naltrexone. American Journal on Addictions. 1993b;2:77-79.
Castro, F.G.; Barrington, E.H.; Sharp, E.V.; Dial, L.S.; Wang. B.; and Rawson, R. Behavioral and psychological profiles of cocaine users upon treatment entry: Ethnic comparisons. Drugs and Society. 1992;6:231-251.
Center for Substance Abuse Research, University of Maryland. Methamphetamine use in the western United States: An in-depth look. Cesar Fax. 1997;6(29).
Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series, No. 1. DHHS Pub. No. (SMA) 93-1991. Washington, DC: U.S. Government Printing Office, 1991.
Center for Substance Abuse Treatment. Improving Treatment for Drug-Exposed Infants. Treatment Improvement Protocol (TIP) Series, No. 5. DHHS Pub. No. (SMA) 95-3057 (reprint). Washington, DC: U.S. Government Printing Office, 1993.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, No. 9. DHHS Pub. No. (SMA) 94-2078. Washington, DC: U.S. Government Printing Office, 1994a.
Center for Substance Abuse Treatment. Assessment and Treatment of Cocaine-Abusing Methadone-Maintained Patients. Treatment Improvement Protocol (TIP) Series, No. 10. DHHS Pub. No. (SMA) 94-3003. Washington, DC: U.S. Government Printing Office, 1994b.
Center for Substance Abuse Treatment. Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, No. 12. DHHS Pub. No. (SMA) 94-3004. Washington, DC: U.S. Government Printing Office, 1994c.
Center for Substance Abuse Treatment. Treatment for HIV-Infected Alcohol and Other Drug Abusers. Treatment Improvement Protocol (TIP) Series, No. 15. DHHS Pub. No. (SMA) 95-3038. Washington, DC: U.S. Government Printing Office, 1995a.
Center for Substance Abuse Treatment. Alcohol and Other Drug Screening of Hospitalized Trauma Patients. Treatment Improvement Protocol (TIP) Series, No. 16. DHHS Pub. No. (SMA) 95-3041. Washington, DC: U.S. Government Printing Office, 1995b.
Center for Substance Abuse Treatment. Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, No. 17. DHHS Pub. No. (SMA) 95-3039. Washington, DC: U.S. Government Printing Office, 1995c.
Center for Substance Abuse Treatment. Detoxification From Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series, No. 19. DHHS Pub. No. (SMA) 95-3046. Washington, DC: U.S. Government Printing Office, 1995d.
Center for Substance Abuse Treatment. Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series, No. 21. DHHS Pub. No. (SMA) 95-3051. Washington, DC: U.S. Government Printing Office, 1995e.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, No. 23. DHHS Pub. No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office, 1996.
Center for Substance Abuse Treatment. Proceedings of the National Consensus Meeting on the Use, Abuse, and Sequelae of Abuse of Methamphetamine With Implications for Prevention, Treatment and Research. DHHS Pub. No. (SMA) 96-8013. Rockville, MD: CSAT, Substance Abuse and Mental Health Services Administration, Department of Health and Human Services, 1997.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series, No. 29. DHHS Pub. No. (SMA) 98-3249. Washington, DC: U.S. Government Printing Office, 1998a.
Center for Substance Abuse Treatment. Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series, No. 30. DHHS Pub. No. (SMA) 98-3245. Washington, DC: U.S. Government Printing Office, 1998b.
Center for Substance Abuse Treatment. Screening and Assessing Adolescents for Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, No. 31. DHHS Pub. No. 99-3282. Washington, DC: U.S. Government Printing Office, 1999a.
Center for Substance Abuse Treatment. Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, No. 32. DHHS Pub. No. 99-3283. Washington, DC: U.S. Government Printing Office, 1999b.
Chafetz, M.E.; Blaine, H.T.; and Hill, M.J. Frontiers of Alcoholism. New York: Science House, 1970.
Chaisson, R.E.; Bacchetti, P.; Osmond, D.; Brodie, B.; Sande, M.A.; and Moss, A.R. Cocaine use and HIV infection in intravenous drug users in San Francisco. Journal of the American Medical Association. 1989;261(4):561-565. [pmid: 2909798].
Chaney, E.F. Social skills training. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches. Elmsford, NY: Pergamon Press, 1989. pp. 206-221.
Charness, M.E. Alcohol and the brain. Alcohol Health and Research World. 1990;14(2):85-89.
Cherek, D.R.; Kelly, T.H.; and Steinberg, J.L. Behavioral contingencies and d-amphetamine effects on human aggressive and non-aggressive responding. In: Harris, L.S., ed. Problems of Drug Dependence, 1986: Proceedings of the 47th Annual Scientific Meeting of the Committee on Problems of Drug Dependence. NIDA Research Monograph Series, Number 67. DHHS Pub. No. (ADM) 86-1448. Rockville, MD: National Institute on Drug Abuse, 1986. pp. 184-189.
Childress, A.R. Cue reactivity and cue reactivity interventions in drug dependence. In: Proceedings of the Symposia on Cocaine Addiction: Trends, Laboratory Research, Clinical Issues, and Treatment. Monograph Series No. 1. The Chemical Dependency Research Working Group. New York State Office of Alcoholism and Substance Abuse Services, 1994. http://www.users.interport.net/~nama/mono1.htm#Helping Cocaine Patients [Accessed October 10, 1997].
Cho, A.K. Ice: A new dosage form of an old drug. Science. 1990;249: 631-634.
Christensen, J.D.; Kaufman, M.J.; Levin, J.M.; Mendelson, J.H.; Holman, B.L.; Cohen, B.M.; and Renshaw, P.F. Abnormal cerebral metabolism in polydrug abusers during early withdrawal using 31P MR spectroscopy. Magnetic Resonance in Medicine. 1996;35:658-663.
Coca-Cola Bottling of Shreveport, Inc., et al. vs. The Coca-Cola Company, a Delaware Corporation, 769 F. Supp. 671.
Cohen, S. Causes of the cocaine outbreak. In: Washton, A.M., and Gold, M.S., eds. Cocaine: A Clinician's Handbook. New York: Guilford Press, 1987. pp. 3-9.
Community Epidemiology Work Group, National Institutes of Health, National Institute on Drug Abuse. Epidemiologic Trends in Drug Abuse. Vol. 1. NIH Pub. No. 96-4126. Rockville, MD: National Institute on Drug Abuse, June 1996a.
Community Epidemiology Work Group, National Institutes of Health, National Institute on Drug Abuse. Epidemiologic Trends in Drug Abuse. Vol. 2. NIH Pub. No. 96-4127. Rockville, MD: National Institute on Drug Abuse, June 1996b.
Community Epidemiology Work Group, National Institutes of Health, National Institute on Drug Abuse. "Epidemiologic Trends in Drug Abuse: Advance Report." Presented at the annual meeting of the Community Epidemiology Work Group, Washington DC, June 24-27. 1997.
Condelli, W.S.; Fairbank, J.A.; Dennis, M.L.; and Rachal, J.V. Cocaine use by clients in methadone programs: Significance, scope, and behavioral interventions. Journal of Substance Abuse Treatment. 1991;8:203-212.
Cook, C.E. Pyrolytic characteristics, pharmacokinetics, and bioavailability of smoked heroin, cocaine, phencyclidine, and methamphetamine. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 6-23.
Cook, C.E.; Jeffcoat, A.R.; Hill, J.M.; Pugh, D.E.; Patetta, P.K.; Sadler, B.M.; White, W.R.; and Perez-Reyes, M. Pharmacokinetics of methamphetamine self-administered to human subjects by smoking S-(+)-MA hydrochloride. Drug Metabolism and Disposition. 1993;21:717-23.
Cooper, J.; Bloom, F.; and Roth, R. The Biochemical Basis of Neuropharmacology, 6th ed. New York: Oxford University Press, 1991.
Cornish, J.W., and O'Brien, C.P. Crack cocaine abuse: An epidemic with many public health consequences. Annual Review of Public Health. 1996;17:259-273.
Corrigan, I.D. Substance abuse as a mediating factor in outcome from traumatic brain injury. Archives of Physical Medicine and Rehabilitation. 1995;76:302-309.
Costello, R.M. Alcoholism treatment and evaluation: In search of methods. II. Collation of two-year follow-up studies. International Journal of the Addictions. 1975;10:251-275.
Cregler, L.L., and Mark, H. Medical complications of cocaine abuse. . New England Journal of Medicine. 1986;315:1495-1500.
Cunningham, J.K., and Thielemeir, M.A. Trends and Regional Variations in Amphetamine-Related Emergency Admissions: California, 1984-1993. Los Angeles, CA: Public Statistics Institute, 1995.
Cunningham, J.K., and Thielemeir, M.A. Trends and Regional Variations in Amphetamine-Related Emergency Admissions: California, 1985-1994. Los Angeles, CA: Public Statistics Institute, 1996.
Czuchry, M.; Dansereau, D.F.; Dees, S.M.; and Simpson, D.D. The use of node-link mapping in drug abuse counseling: The role of attentional factors. Journal of Psychoactive Drugs. 1995;27:161-166.
Dansereau, D.F.; Joe, G.W.; and Simpson, D.D. Attentional difficulties and the effectiveness of a visual representation strategy for counseling drug-addicted clients. International Journal of the Addictions. 1995;30:371-386.
Daras, M. Neurologic complications of cocaine. In: Majewska, M.D., ed. Neurotoxicity and Neuropathology Associated With Cocaine Abuse. NIDA Research Monograph Series, Number 163. DHHS Pub. No. (ADM) 96-4019. Rockville, MD: National Institute on Drug Abuse, 1996. pp. 43-65.
Des Jarlais, D.C., and Friedman, S.R. HIV epidemiology and interventions among injecting drug users. International Journal of STDs and AIDS. 1996;7 (suppl) 2:57-61.
Di Chiara, G. The role of dopamine in drug abuse viewed from the perspective of its role in motivation. Drug and Alcohol Dependence. 1995;38:95-137.
Di Chiara, G. Alcohol and dopamine. Alcohol Health and Research World. 1997;21(2):108-114. [pmid: 15704345].
Drug Enforcement Administration. The Cocaine Threat to the United States. Washington, DC: Department of Justice, Drug Enforcement Administration, 1995.
Drug Enforcement Administration. Methamphetamine Situation in the United States: Drug Intelligence Report. Washington, DC: Department of Justice, Drug Enforcement Administration, 1996.
Drug Enforcement Agency. 1996 National Narcotics Intelligence Consumers Committee Report: The Supply of Illicit Drugs to the United States. Washington, DC: Department of Justice, Drug Enforcement Administration, 1997.
Dunteman, G.H.; Condelli, W.S.; and Fairbank, J.A. Predicting cocaine use among methadone patients: Analysis of findings from a national study. Hospital and Community Psychiatry. 1992;43:608-611.
Elk, R. Pregnant women and TB-exposed drug abusers: Reducing drug use and increasing treatment compliance. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, in press.
Ellinwood, E.H., Jr. The epidemiology of stimulant abuse. In: Josephson, E., and Carroll, E.E., eds. Drug Use: Epidemiological and Sociological Approaches. Washington, DC: Hemisphere, 1974.
Ellinwood, E.H., Jr. Emergency treatment of adverse reactions to CNS stimulants. A Treatment Manual for Acute Drug Abuse Emergencies. DHEW Pub. No. (ADM) 76-230. Rockville, MD: Alcohol, Drug Abuse and Mental Health Administration, 1975.
Ellinwood, E.H., Jr., and Lee, T.H. Dose- and time-dependent effects of stimulants. In: Asghar, K., and De Souza, E., eds. Pharmacology and Toxicology of Amphetamine and Related Designer Drugs. NIDA Research Monograph Series, Number 94. DHHS Pub. No. (ADM) 89-1640. Rockville, MD: National Institute on Drug Abuse, 1989. pp. 323-340.
Ellinwood, E.H., Jr.; Sudilovsky, A.; and Nelson, L.M. Evolving behavior in the clinical and experimental amphetamine (model) psychosis. American Journal of Psychiatry. 1973;130:1088-1093.
Fals-Stewart, W.; Birchler, G.R.; and O'Farrell, T.J. Behavioral couples therapy for male substance-abusing patients: Effects on relationship adjustment and drug-seeking behavior. Journal of Consulting and Clinical Psychology. 1996;64:959-972.
Festinger, D.S.; Lamb, R.J.; Kirby, K.C.; and Marlowe, D.B. The accelerated intake: A method for increasing initial attendance to outpatient cocaine treatment. Journal of Applied Behavioral Analysis. 1996;29:387-389.
Festinger, D.S.; Lamb, R.J.; Kountz, M.; Kirby, K.C.; and Marlowe, D.B. Pre-treatment dropout as a function of treatment delay and client variables. Addictive Behaviors. 1995;20:111-115.
Feucht, T.E., and Kyle, G.M. Methamphetamine use among adult arrestees: Findings from the Drug Use Forecasting (DUF) program. National Institute of Justice Research in Brief. 1996;NCJ 161842, Nov.
Friedman, L.M.; Furberg, C.D.; and DeMets, D.L. Fundamentals of Clinical Trials. Boston: John Wright, PSG, 1983.
Frosch, D.; Shoptaw, S.; Huber, A.; Rawson, R.A.; and Ling, W. Sexual HIV risk among gay and bisexual male methamphetamine abusers. Journal of Substance Abuse Treatment. 1996;13(6):483-486. [pmid: 9219145].
Gawin, F.H., and Ellinwood, E.H., Jr. Cocaine and other stimulants-actions, abuse, and treatment. New England Journal of Medicine. 1988;318:1173-1182.
Gawin, F.H., and Khalsa-Denison, M.E. Is craving mood-driven or self-propelled? Sensitization and "street" stimulant addiction. In: Majewska, M.D., ed. Neurotoxicity and Neuropathology Associated With Cocaine Abuse. NIDA Research Monograph Series, Number 163. DHHS Pub. No. (ADM) 96-4019. Rockville, MD: National Institute on Drug Abuse, 1996. pp. 224-250.
Gawin, F.H., and Kleber, H.D. Cocaine abuse treatment. Open pilot trial with desipramine and lithium carbonate. Archives of General Psychiatry. 1984;41:903-909.
Gawin, F.H., and Kleber, H.D. Abstinence symptomatology and psychiatric diagnosis in cocaine abusers. Archives of General Psychiatry. 1986;43:107-113.
Gawin, F.H.; Kleber, H.D.; Byck, R.; Rounsaville, B.J.; Kosten, T.R.; Jatlow, P.I.; and Morgan, C. Desipramine facilitation of initial cocaine abstinence. Archives of General Psychiatry. 1989;46:117-121.
Gerstein, D.R.; Johnson, R.A.; Harwood, H.J.; Fountain, D.; Suter, N.; Malloy, K., eds. Evaluating Recovery Services: The California Drug and Alcohol Treatment Assessment (CALDATA). Washington, DC: National Academy Press, 1994.
Gold, M.S. Cocaine (and crack): Clinical aspects. In: Lowinson, J.H.; Ruiz, P.; Millman, R.B.; and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook, 3rd ed. Baltimore: Williams & Wilkins, 1997.
Gold, M.S., and Miller, N.S. Cocaine (and crack): Neurobiology. In: Lowinson, J.H.; Ruiz, P.; Millman, R.B.; and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook, 3rd ed. Baltimore: Williams & Wilkins, 1997.
Goldfrank, L.R., and Hoffman, R. S. The cardiovascular effects of cocaine--update 1992. In: Sorer, H., ed. Acute Cocaine Intoxication: Current Methods of Treatment. NIDA Research Monograph Series, Number 123. DHHS Pub. No. (ADM) 93-3498. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 70-109.
Golub, A.L., and Johnson, B.D. Crack's decline: Some surprises across U.S. cities. National Institute of Justice Research in Brief. 1997;July.
Goode, E. Drugs in American Society, 4th ed. New York: McGraw-Hill, 1993.
Gorelick, D.A. Pharmacologic therapies for cocaine addiction. In: Miller, N.S., and Gold, M., eds. Pharmacological Therapies for Alcohol and Drug Addictions. New York: Marcel Dekker, 1994. pp. 143-157.
Gorski, T., and Miller, M. Staying Sober: A Guide for Relapse Prevention. Independence, MO: Independence Press, 1986.
Gottleib, A. The Pleasures of Cocaine. Berkeley, CA: And/or Press, 1976.
Grabowski, J.; Rhoades, H.; Elk, R.; Schmitz, J.; Davis, C.; Creston, D.; and Kirby, K. Fluoxetine is ineffective for treatment of cocaine dependence and concurrent opiate dependence: Two placebo controlled double-blind trials. Journal of Clinical Psychopharmacology. 1995;15:163-174.
Grant, B.F., and Harford, T.C. Concurrent and simultaneous use of alcohol with cocaine: Results of national survey. Drug and Alcohol Dependence. 1990;25:97-104.
Grant, S.; London, E.D.; Newlin, D.B.; Villemagne, V.L.; Liu, X.; Contoreggi, C.; Phillips, R.L.; Kimes, A.S.; and Margolin, A. Activation of memory circuits during cue-elicited cocaine craving. Proceedings of the National Academy of Sciences. 1995;93:12040-12045.
Griffith, J.D.; Cavanaugh, J.; Held, J.; and Oates, J.A. Dextroamphetamine: Evaluation of psychomimetic properties in man. Archives of General Psychiatry. 1972;26(2):97-100. [pmid: 4551260].
Hall, J.N.; Uchman, R.S.; and Dominguez, R. Trends and Patterns of Methamphetamine Use in the United States. Report prepared for the Department of Epidemiology and Statistical Analysis. NIDA Order No. 88MO31054801D. Miami, FL: Up Front Drug Information Center, 1988.
Hall, S.M.; Tunis, S.; Triffleman, E.; Banys, P.; Clark, H.W.; Tusel, D.; Stewart, P.; and Presti, D. Continuity of care and desipramine in primary cocaine abusers. Journal of Nervous and Mental Disease. 1994;182:570-575.
Hando, J., and Hall, W. Patterns of amphetamine use in Australia. In: Klee, H. ed. Amphetamine Misuse: International Perspectives on Current Trends. Amsterdam: Harwood Academic Publishers, 1997.
Havassy, B.E.; Wasserman, D.A.; and Hall, S.M. Relapse to cocaine use: Conceptual issues. In: Tims, F.M., and Leukefeld, C.G., eds. Cocaine Treatment: Research and Clinical Perspectives. NIDA Research Monograph Series, Number 135. DHHS Pub. No. (ADM) 93-3639. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 203-217.
Hawks, R.L., and Chiang, C.N. Examples of specific drug assays. In: Hawks, R.L., and Chiang, C.N., eds. Urine Testing for Drugs of Abuse. NIDA Research Monograph Series, Number 73. DHHS Pub. No. (ADM) 87-1481. Rockville, MD: National Institute on Drug Abuse, 1986. pp. 84-112.
Heischobar, B., and Miller, M.A. Methamphetamine abuse in California. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 60-71.
Herning, R.I.; Guo, X.; Better, W.E.; Weinhold, L.L.; Lange, W.R.; Cadet, J.L.; and Gorelick, D.A. Neurophysiological signs in cocaine dependence: Increased EEG beta during withdrawal. Biological Psychiatry. 1997;41:1087-1094.
Higgins, S.T., and Budney, A.J. Treatment of cocaine dependence through the principles of behavior analysis and behavioral pharmacology. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Behavioral Treatments for Drug Abuse and Dependence. NIDA Research Monograph Series, Number 137. NTIS Pub. No. 94-169570. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 97-121.
Higgins, S.T., and Budney, A.J. From the initial clinic contact to aftercare: A brief review of effective strategies for retaining cocaine abusers in treatment. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug-Dependent Individual in Treatment. NIDA Research Monograph Series, Number 165. DHHS Pub. No. (ADM) 97-4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 25-43.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Foerg, F.E.; and Badger, G.J. Alcohol dependence and simultaneous cocaine and alcohol use in cocaine-dependent patients. Journal of Addictive Diseases. 1994a.;13:177-189.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Foerg, F.E.; Donham, R.; and Badger, G.J. Incentives improve treatment retention and cocaine abstinence in ambulatory cocaine-dependent patients. outcome in outpatient behavioural treatment of cocaine dependence. Archives of General Psychiatry. 1994;51:568-576.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Foerg, F.E.; Ogden, D.; and Badger, G.J. Outpatient behavioral treatment for cocaine dependence: One-year outcome. Experimental and Clinical Psychopharmacology. 1995;3:205-212.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; and Foerg, F. Disulfiram therapy in patients abusing cocaine and alcohol. American Journal of Psychiatry. 1993a;150:675-676.
Higgins, S.T.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Badger, G. Achieving cocaine abstinence with a behavioral approach. American Journal of Psychiatry. 1993b.;150:736-769.
Higgins, S.T.; Delaney, D.D.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Fenwick, J.W. A behavioral approach to achieving initial cocaine abstinence. American Journal of Psychiatry. 1991;148:1218-1224.
Higgins, S.T.; Roll, J.M.; and Bickel, W.K. Alcohol pretreatment increases preference for cocaine over monetary reinforcement. Psychopharmacology. 1996;123:1-8.
Higgins, S.T., and Wong, C.J. Treating cocaine abuse: What does research tell us? In: Higgins, S.T., and Katz, J.L., eds. Cocaine Abuse Research: Pharmacology, Behavior, and Clinician Application. San Diego, CA: Academic Press, 1998.
Higgins, S.T.; Wong, C.J.; Budney, A.J.; English, K.T.; and Kennedy, M.H. Efficacy of incentives during outpatient behavioral treatment for cocaine dependence [abstract]. In: Harris, L.S., ed. Problems of Drug Dependence 1996: Proceedings of the 58th Annual Scientific Meeting of the College on Problems of Drug Dependence. NIDA Research Monograph Series, Number 174. DHHS Pub. No. (ADM) 97-4236. Rockville, MD: National Institute on Drug Abuse, 1997. p. 75.
Hiller-Sturmhfel, S. Signal transmission among nerve cells. Alcohol Health and Research World. 1995;19(2):128.
Hoff, A.L.; Riordan, H.; Morris, L.; Cestaro, V.; Wienke, M.; Alpert, R.; Wang, G.J.; and Volkow, N. Effects of crack cocaine on neurocognitive function. . Psychiatry Research. 1996;60:167-176.
Huber, A.; Ling, W.; Shoptaw, S.; Gulati, V.; Brethen, P.; and Rawson, R. Integrating treatments for methamphetamine abuse: A psychosocial perspective. Journal of Addictive Diseases. 1997;16(4):41-50. [pmid: 9328808].
Hughes, P.H.; Coletti, S.D.; Neri, R.L.; Umann, C.F.; Stahl, S.; Sicilian, D.M.; and Anthony, J.C. Retaining cocaine-abusing women in a therapeutic community: The effect of a child live-in program. American Journal of Public Health. 1995;85:1149-1152.
Hurley, S.F.; Jolley, D.J.; Kaldor, J.M. Effectiveness of needle-exchange programmes for prevention of HIV infection. Lancet. 1997;349(9068):1797-1800. [pmid: 9269214].
Iguchi, M.Y.; Belding, M.A.; Morral, A.R.; Lamb, R.J.; and Husband, S.D. Reinforcing operants other than abstinence in drug abuse treatment: An effective alternative for reducing drug use. Journal of Consulting and Clinical Psychology. 1997;65:421-428.
Inaba, D.; Cohen, W.E.; and Holstein, M.E. Uppers, Downers, All Arounders: Physical and Mental Effects of Psychoactive Drugs, 2nd ed. Ashland, OR: CNS Productions, 1993.
Institute of Medicine. Preventing HIV Transmission: The Role of Sterile Needles and Bleach. Normand, J.; Vlahov, D.; and Moses, L.E., eds. Washington, DC: National Academy Press, 1995.
Irvine, G.D., and Chin, L. The environmental impact and adverse health effects of clandestine manufacture of methamphetamine. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 33-46.
Iyo, M.; Nishio, M.; Itoh, T.; Fukuda, H.; Suzuki, K.; Yamasaki, T.; Fukui, S.; and Tateno, Y. Dopamine D2 and serotonin S2 receptors in susceptibility to methamphetamine psychosis detected by positron emission tomography. Psychiatry Research. 1993;50:217-228.
Jenkins, S.W.; Warfield, N.A.; Blaine, J.D.; Cornish, J.; Ling, W.; Rosen, M.I.; Urschel, H.; Wesson, D.; and Ziedonis, D. A pilot trial of gepirone vs. placebo in the treatment of cocaine dependency. Psychopharmacology Bulletin. 1992;28:21-26.
Jeri, F.R. Coca-paste smoking in some Latin American countries: A severe and unabated form of addiction. Bulletin on Narcotics. 1984;36(2):15-31. [pmid: 6569819].
Joe, G.W.; Dansereau, D.F.; and Simpson, D.D. Node-link mapping for counseling cocaine users in methadone treatment. Journal of Substance Abuse. 1994;6:393-406.
Johanson, C.E., and Fischman, M.W. The pharmacology of cocaine related to its abuse. Pharmacological Reviews. 1989;41:3-52.
Johnson, R.E.; Eisenberg, Eissenberg, T.; Stitzer, M.L.; Strain, E.C.; Liebson, I.A.; and Bigelow, G.E. A placebo controlled clinical trial of buprenorphine as a treatment of opioid dependence. Drug and Alcohol Dependence. 1995;40:17-25.
Kang, S.Y.; Kleinman, P.H.; Woody, G.E.; Millman, R.B.; Todd, T.C.; Kemp, J.; and Lipton, D.S. Outcomes for cocaine abusers after once-a-week psychosocial therapy. American Journal of Psychiatry. 1991;148(5):630-635. [pmid: 1850208].
Khalsa, H.K.; Kowalewski, M.R.; Anglin, M.D.; and Wang, J. HIV-related risk behaviors among cocaine users. AIDS Education and Prevention. 1992;4(1):71-83. [pmid: 1311941].
Kidorf, M., and Stitzer, M.L. Contingent access to methadone maintenance treatment: Effects on cocaine use of mixed cocaine-opiate abusers. Experimental and Clinical Psychopharmacology. 1993;1:200-206.
King, G.R., and Ellinwood, E.H. Amphetamines and other stimulants. In: Lowinson, J.H.; Ruiz, P.; Millman, R.B.; and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook, 3rd ed. Baltimore: Williams & Wilkins. 1997.
Kirn, W. Crank. Time Magazine. 1998;151(24):June 22.
Kissin, B.; Platz, A.; and Su, W.H. Selective factors in treatment choice and outcome in alcoholics. In: Mello, N.K., and Mendelson, J.H., eds. Recent Advances in Studies of Alcoholism. Washington, DC: U.S. Government Printing Office. 1971.
Kleber, H.D. Pharmacotherapy, current and potential, for the treatment of cocaine dependence. Clinical Neuropharmacology. 1995;18(suppl. 1):S96-S109.
Koob, G.F. Drugs of abuse: Anatomy, pharmacology and function of reward pathways. Trends in Pharmacological Sciences. 1992;13:177-184.
Koob, G.F., and Le Moal, M. Drug abuse: Hedonic homeostatic dysregulation. Science. 1997;278:52-58.
Kosten, T.R.; Rosen, M.I.; Schottenfeld, R.; and Ziedonis, D. Buprenorphine for cocaine and opiate dependence. Psychopharmacology Bulletin. 1992;28:15-19.
Kral, A.H.; Bluthenthal, R.N.; Booth, R.E.; and Watters, J.K. HIV seroprevalence among street-recruited injection drug and crack cocaine users in 16 US municipalities. American Journal of Public Health. 1998;88(1):108-113. [pmid: 9584014].
Kramer, J.C. Introduction to amphetamine abuse. Journal of Psychedelic Drugs. 1969;2:8-13.
Kranzler, H.R.; Bauer, L.O.; Hersh, D.; and Klinghoffer, V. Carbamazepine treatment of cocaine dependence: A placebo-controlled trial. Drug and Alcohol Dependence. 1995;38:203-211.
Kreek, M.J. Opiates, opioids and addiction. Molecular Psychiatry. 1996;1:232-254.
Lago, J.A., and Kosten, T.R. Stimulant withdrawal. Addiction. 1994;89:1477-1481.
Landry, M. An overview of cocaethylene, an alcohol-derived psychoactive cocaine metabolite. Journal of Psychoactive Drugs. 1992;24:273-276.
Landry, M. Understanding Drugs of Abuse: The Processes of Addiction, Treatment, and Recovery. Washington, DC: American Psychiatric Press, 1994.
Landry, M. Overview of Addiction Treatment Effectiveness. Rockville, MD: Substance Abuse and Mental Health Services Administration, Office of Applied Studies, 1995.
Landry, M. Alcoholics Anonymous: Review of the Research. Rockville, MD: Substance Abuse and Mental Health Services Administration, Office of Applied Studies, in press.
Leshner, A.I. Addiction is a brain disease, and it matters. . Science. 1997;278:45-47.
Leshner, A.I. Treatment: Effects on the brain and body. In: Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. The National Methamphetamine Drug Conference: Conference Proceedings, May 28-30, 1997, Omaha, Nebraska. Sponsored by ONDCP. Washington, DC: ONDCP, 1998. http://www.whitehousedrugpolicy.gov/drugfact/methconf/plenary2.html [Accessed June 23, 1998].
Lieberman, M.A.; Yalom, I.D.; and Miles, M.B. Encounter Groups: First Facts. New York: Basic Books, 1973.
Ling, W., and Shoptaw, S. Integration of research in pharmacotherapy for addictive disease: Where are we? Where are we going?. Journal of Addictive Diseases. 1997;16:83-102.
London, E.D.; Cascella, N.G.; Wong, D.F.; Phillips, R.L.; Dannals, R.F.; Links, J.M.; Herning, R.; Grayson, R.; Jaffe, J.H.; and Wagner, H.N., Jr. Cocaine-induced reduction of glucose utilization in human brain. Archives of General Psychiatry. 1990;47(6):567-574. [pmid: 2350209].
Lukas, S.E.; Sholar, M.; Lundahl, L.H.; Lamas, X.; Kouri, E.; Wines, J.D.; Kragie, L.; and Mendelson, J.H. Sex differences in plasma cocaine levels and subjective effects after acute cocaine administration in human volunteers. Psychopharmacology. 1996;125(4):346-354. [pmid: 8826539].
Lurie, P., and Drucker, E. An opportunity lost: HIV infections associated with lack of a national needle-exchange programme in the USA. Lancet. 1997;349(9052):604-608. [pmid: 9057732].
Majewska, M.D. Cocaine addiction as a neurological disorder: Implications for treatment. In: Majewska, M.D., ed. Neurotoxicity and Neuropathology Associated with Cocaine Abuse. NIDA Research Monograph Series, Number 163. DHHS Pub. No. (ADM) 96-4019. Rockville, MD: National Institute on Drug Abuse, 1996. pp. 1-26.
Marlatt, G.A., and Gordon, J.R. Relapse Prevention. New York: Guilford Press, 1985.
McCrady, B.S.; Noel, N.E.; Abrams, D.B.; Stout, R.L.; Nelson, H.F.; and Hay, W.M. Comparative effectiveness of three types of spouse involvement in outpatient behavioral alcoholism treatment. Journal of Studies on Alcohol. 1986;47(6):459-467. [pmid: 3795960].
McLellan, A.T.; Arndt, I.O.; Metzger, D.S.; Woody, G.E.; and O'Brien, C.P. The effects of psychosocial services in substance abuse treatment. Journal of the American Medical Association. 1993;269:1953-1996.
Melega, W.P.; Raleigh, M.J.; Stout, D.B.; Huang, S.-C.; and Phelps, M.E. Ethological and 6-[18F]fluor-l-DOPA-PET profiles of long-term vunerability to chronic amphetamine. Behavioural Brain Research. 1997a;84:259-268.
Melega, W.P.; Raleigh, M.J.; Stout, D.B.; Lacan, G.; Huang, S.C.; and Phelps, M.E. Recovery of striatal dopamine function after acute amphetamine- and methamphetamine-induced neurotoxicity in the vervet monkey. Brain Research. 1997b.;766(1-2):113-120.
Mendelson, J.; Jones, R.T.; Upton, R.; and Jacob, P. III. Methamphetamine and ethanol interactions in humans. Clinical Pharmacology and Therapeutics. 1995;57(5):559-568. [pmid: 7768079].
Mendelson, J.H., and Mello, N.K. Management of cocaine abuse and dependence. New England Journal of Medicine. 1996;334:965-972.
Metzger, D.S.; Woody, G.E.; McLellan, A.T.; O'Brien, C.P.; Druley, P.; Navaline, H.; DePhilippis, D.; Stolley, P.; and Abrutyn, E. Human immunodeficiency virus seroconversion among intravenous drug users in- and out- of treatment: An 18-month prospective follow-up. Journal of Acquired Immune Deficiency Syndrome. 1993;6(9):1049-1056.
Meyers, R.J., and Smith, J.E. Clinical Guide to Alcohol Treatment: The Community Reinforcement Approach. New York: Guilford Press, 1995.
Miczek, K.A. Psychopharmacology of aggression. In: Iversen, L.L.; Snyder, S.H.; Iversen, S.D., eds. Handbook of Psychopharmacology. Vol. 19. New York: Plenum Press, 1987. pp. 183-328.
Miczek, K.A., and Tidey, J.W. Amphetamines: Aggressive and social behavior. In: Asghar, K., and De Souza, E., eds. Pharmacology and Toxicology of Amphetamine and Related Designer Drugs. NIDA Research Monograph Series, Number 94. DHHS Pub. No. (ADM) 89-1640. Rockville, MD: National Institute on Drug Abuse, 1989. pp. 68-100.
Milby, J.B.; Schumacher, J.E.; Raczynski, J.M.; Caldwell, E.; Engle, M.; Michael, M.; and Carr, J. Sufficient conditions for effective treatment of substance abusing homeless persons. Drug and Alcohol Dependence. 1996;43:23-38.
Miller, B.L.; Chiang, F.; McGill, L.; Sadow, T.; Goldberg, M.A.; and Mena, I. Cerebrovascular complications from cocaine: Possible long-term sequelae. In: Sorer, H., ed. Acute Cocaine Intoxication: Current Methods of Treatment. NIDA Research Monograph Series, Number 123. DHHS Pub. No. (ADM) 93-3498. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 129-146.
Miller, M., and Kozel, N.J. Introduction and overview. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 1-5.
Miller, W.R. Motivation for treatment: A review with special emphasis on alcoholism. Psychological Bulletin. 1985;98:84-107.
Miller, W.R. Increasing motivation for change. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives, 2nd ed. Boston: Allyn & Bacon, 1995. pp. 89-104.
Miller, W.R., and Munoz, R.F. How to Control Your Drinking, rev. ed. Albuquerque, NM: University of New Mexico Press, 1982.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People to Change Addictive Behavior. New York: Guilford Press, 1991.
Milmoe, S.; Rosenthal, R.; Blane, H.T.; Chafetz, M.E.; and Wolf, I. The doctor's voice: Postdictor of successful referral of alcoholic patients. Journal of Abnormal Psychology. 1967;48:590-84.
Monti, P.M.; Rohsenow, D.J.; Colby, S.M.; and Abrams, D.B. Coping and social skills training. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives, 2nd ed. Boston: Allyn & Bacon, 1995. pp. 221-241.
Mori, A.; Suzuki, H.; and Ishiyama, I. Three cases of acute methamphetamine intoxication: Analysis of optically active methamphetamine. Nippon Hoigaku Zasshi. 1992;46(4): 266-270.
Mueller, M.D., and Wyman, J.R. Study sheds new light on the state of drug abuse treatment nationwide. NIDA Notes. 1997;12(5):1-7.
Nash, J.M. Addicted. Time. 1997;149(18):69-76.
National Institute of Justice (NIJ), Office of Justice Programs, Department of Justice. Crack, Powder Cocaine, and Heroin: Drug Purchase and Use Patterns in Six U.S. Cities. ONDCP Research Report NCJ 167265. Washington, DC: National Institute of Justice, 1997a.
National Institute of Justice (NIJ), Office of Justice Programs, Department of Justice. Drug Use Forecasting: 1996 Annual Report on Adult and Juvenile Arrestees. Washington, DC: National Institute of Justice, 1997b.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Eighth Special Report to the U.S. Congress on Alcohol and Health From the Secretary of Health and Human Services, September 1993. NIH Pub. No. 94-3699. Bethesda, MD: National Institutes of Health, 1994.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Neuroscience research and medications development. Alcohol Alert. 1996;33(PH 366).
National Institute on Drug Abuse (NIDA). Methamphetamine Abuse. NIDA Capsule Series (C-89-06). Revised September 1997. Http://165.112.78.61/NIDA Capsules/NCMethamphetamine.html [Accessed May 4, 1998].
National Institute on Drug Abuse (NIDA). Methamphetamine: Abuse and Addiction. NIDA Research Report Series. NIH Pub. No. 98-4210. Rockville, MD: National Institute on Drug Abuse, April 1998a.
National Institute on Drug Abuse. Monitoring the Future Study, High School and Youth Trends. Rockville, MD: National Institute on Drug Abuse, 1998b. http://www.nida.nih.gov/NIDACapsules/NCMTFuture.html [Accessed May 5, 1998].
National Institute on Drug Abuse. NIDA expands research to meet challenge of methamphetamine abuse. NIDA Notes. 1998c.;Volume 13.
Nestler, E.J., and Aghajanian, G.K. Molecular and cellular basis of addiction. Science. 1997;278:58-63.
Nestor, T.A.; Tamamoto, W.I.; Kam, T.H.; and Schultz, T. Acute pulmonary oedema caused by crystalline methamphetamine. Lancet. 1989;2(8674):1277-1278. [pmid: 2573788].
Nunes, E.V.; McGrath, P.J.; Quitkin, F.M.; Ocepek-Welikson, K.; Stewart, J.W.; Koenig, T.; Wager, S.; and Klein, D.F. Imipramine treatment of cocaine abuse: Possible boundaries of efficacy. Drug and Alcohol Dependence. 1995;39:185-195.
Obert, J.L.; Rawson, R.A.; and Miotto, K. Substance abuse treatment for "hazardous users": An early intervention. Journal of Psychoactive Drugs. 1997;29(3):291-298. [pmid: 9339862].
O'Brien, C.P.; Childress, A.R.; McLellan, A.T.; and Ehrman, R. Developing treatments that address classical conditioning. In: Tims, F.M., and Leukefeld, C.G., eds. Cocaine Treatment: Research and Clinical Perspectives. NIDA Research Monograph Series, Number 135. DHHS Pub. No. (ADM) 93-3639. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 71-91.
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. Street Terms: Drugs and the Drug Trade. ONDCP Drugs and Crime Data, Drugs and Crime Clearinghouse. ONDCP Research Report NCJ 151622. Washington, DC: Office of National Drug Control Policy, 1995.
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. National Methamphetamine Strategy. Washington, DC: Office of National Drug Control Policy, April 1996.
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. Pulse Check: Methamphetamine Trends in Five Western States and Hawaii. Washington, DC: Office of National Drug Control Policy, January 1997a. http://www.whitehousedrugpolicy.gov/drugfact/pulsechk/pcappa.html [Accessed January 19, 1998].
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. Pulse Check: National Trends in Drug Abuse. Washington, DC: Office of National Drug Control Policy, Winter 1997b. http://www.whitehousedrugpolicy.gov/drugfact/pulsechk/pcindex.html [Accessed January 19, 1998].
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. Cocaine: Facts and Figures. ONDCP Drugs and Crime Data, Drugs and Crime Clearinghouse. Pub. No. PK 24. Rockville, MD: Office of National Drug Control Policy, 1998a.
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. Methamphetamine: Facts and Figures. ONDCP Drug Policy Information Clearinghouse. Pub. No. PK 29. Rockville, MD: Office of National Drug Control Policy, 1998b.
Office of National Drug Control Policy (ONDCP), Office of Justice Programs, Department of Justice. The National Methamphetamine Drug Conference: Conference Proceedings, May 28-30, 1997, Omaha, Nebraska. Washington, DC: Office of National Drug Control Policy, 1998c.
O'Malley, S.; Adamse, M.; Heaton, R.K.; and Gawin, F.H. Neuropsychological impairment in chronic cocaine abusers. American Journal of Drug and Alcohol Abuse. 1992;18:131-144.
Oro, A.S., and Dixon, S.D. Perinatal cocaine and methamphetamine exposure: Maternal and neonatal correlates. Journal of Pediatrics. 1987;111: 571-578.
Parker, M.W.; Winstead, D.K.; and Willi, F.J. Patient autonomy in alcohol rehabilitation: I. Literature Review. International Journal of the Addictions. 1979;14:1015-1022.
Paul, J.P.; Stall, R.; and Bloomfield, K.A. Gay and alcoholics. Alcohol Health and Research World. 1991;15(2):151-160.
Paul, J.P.; Stall, R.D.; Crosby, G.M.; Barrett, D.C.; and Midanik, L.T. Correlates of sexual risk-taking among gay male substance abusers. Addiction. 1994;89(8):971-983. [pmid: 7950855].
Paul, J.P.; Stall, R.; and Davis, F. Sexual risk for HIV transmission among gay/bisexual men in substance-abuse treatment. AIDS Education and Prevention. 1993;5(1):11-24. [pmid: 8481269].
Peat, M.A.; Warren, P.F.; and Gibb, J.W. Effects of single dose of methamphetamine and iprindole on the serotonergic and dopaminergic system of the rat brain. Journal of Pharmacological and Experimental Therapy. 1983;225:126-131.
Petersen, R.C. "Methamphetamine abuse research--a review." Unpublished manuscript. Rockville, MD: Center for Substance Abuse Treatment. 1996.
Pettinati, H. Diagnosing personality disorders in substance abusers. In: Harris, L.S., ed. Problems of Drug Dependence, 1990: Proceedings of the 54th Annual Scientific Meeting of the Committee on Problems of Drug Dependence. NIDA Research Monograph Series, Number 105. DHHS Pub. No. (ADM) 91-1753. Rockville, MD: Institute on Drug Abuse, 1991. pp. 236-242.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. In search of how people change: Applications to addictive behaviors. American Psychologist. 1992;47:1102-1114.
Rabin, S.M., and Little, B.B. Peripartum methamphetamine use in a large urban population. Journal of Maternal and Fetal Medicine. 1994;3:101-103.
Rawson, R.A. Relapse prevention programming in the treatment of opioid users. . Substance Abuse Bulletin. 1986;2:1-5.
Rawson, R.A.; Huber, A.; Brethen, P.; and Ling, W. "Treatment response and treatment outcome of methamphetamine and cocaine users." Presented at American Society of Addiction Medicine, New Orleans, Louisiana. 1998a.
Rawson, R.A.; Huber, A.; Brethen, P.; Shoptaw, S.; and Ling, W. "Methamphetamine and cocaine: Comparison of reported effects and response to treatment." Presented at CPDD Satellite Conference on Methamphetamine, San Juan, Puerto Rico. 1996.
Rawson, R.A.; Obert, J.L.; and McCann, M.J. The Matrix Intensive Outpatient Program Therapist Manual. Los Angeles, CA: The Matrix Center, Inc., 1995.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; Castro, F.G.; and Ling, W. Cocaine abuse treatment: A review of current strategies. Journal of Substance Abuse. 1991a;3(4): 457-491.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; and Ling, W. The Matrix Model of Outpatient Treatment for Alcohol Use and Dependency. Beverly Hills, CA: The Matrix Center, Inc., 1991b.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; and Ling, W. Neurobehavioral treatment for cocaine dependency: A preliminary evaluation. In: Tims, F.M., and Leukefeld, C.G., eds. Cocaine Treatment: Research and Clinical Perspectives. NIDA Research Monograph Series, Number 135. DHHS Pub. No. (ADM) 93-3639. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 92-115.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; and Mann, A.J. Cocaine treatment outcome: Cocaine use following inpatient, outpatient, and no treatment. In: Harris, L.S., ed. Problems of Drug Dependence, 1986: Proceedings of the 47th Annual Scientific Meeting, the Committee on Problems of Drug Dependence. NIDA Research Monograph Series, Number 67. DHHS Pub. No. (ADM) 86-1448. Rockville, MD: National Institute on Drug Abuse, 1986. pp. 271-277.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; Smith, D.P., and Ling, W. Neurobehavioral treatment for cocaine dependency. Journal of Psychoactive Drugs. 1990;22:159-171.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; Smith, D.P.; and Scheffey, E.H. The Neurobehavioral Treatment Manual. Beverly Hills, CA: The Matrix Center, Inc., 1989.
Rawson, R.A.; Shoptaw, S.J.; Obert, J.L.; McCann, M.J.; Hasson, A.L.; Marinelli-Casey, P.J.; Brethen, P.R.; and Ling, W. An intensive outpatient approach for cocaine abuse treatment: The Matrix Model. Journal of Substance Abuse Treatment. 1995;12:117-127.
Rawson, R.A.; Washton, A.M.; and Shoptaw, S. "Psychoactive substance use and sexual behavior: A study and analysis." Presented at the American Society of Addiction Medicine, New Orleans, Louisiana. 1998b.
Renton, A.; Whitaker, L.; Ison, C.; Wadsworth, J.; and Harris, J.R. Estimating the sexual mixing patterns in the general population from those in people acquiring gonorrhea infection: Theoretical foundation and empirical findings. . Journal of Epidemiology and Community Health. 1995;49:205-213.
Restak, R.R. The Mind. New York: Bantam Books, 1988.
Ricuarte, Ricaurte, G.A.; Schuster, C.R.; and Seiden, L.S. Long-term effects of repeated methylamphetamine administration on dopamine and serotonin neurons in the rat brain: A regional study. Brain Research. 1980;193:153-163.
Robbins, T.W.; Cador, M.; Taylor, J.R.; and Everitt, B.J. Limbic striatal interactions in reward-related processes. Neuroscience and Biobehavioral Reviews. 1989;13:155-162.
Robinson, T.E., and Becker, J.B. Enduring changes in brain and behavior produced by chronic amphetamine administration: A review and evaluation of animal models of amphetamine psychosis. Brain Research. 1986;396:157-198.
Roll, J.M.; Higgins, S.T.; Steingard, S.; and McGinley, M. Use of monetary reinforcement to reduce the cigarette smoking of persons with schizophrenia: A feasibility study. Experimental and Clinical Psychopharmacology. 1998;6:157-161.
Rounsaville, B., and Caroll, K. Psychiatric disorders in treatment-entering cocaine abusers. In: Schober, S., and Schade, C., eds. Epidemiology of Cocaine Use and Abuse. NIDA Research Monograph Series, Number 110. DHHS Pub. No. (ADM) 91-1787. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 227-251.
Rowan-Szal, G.; Joe, G.W.; Chatham, L.R.; and Simpson, D.D. A simple reinforcement system for methadone clients in a community-based treatment program. Journal of Substance Abuse Treatment. 1994;11:217-223.
Rowbotham, M.C. Cocaine levels and elimination in inpatients and outpatients: Implications for emergency treatment of cocaine complications. In: Sorer, H., ed. Acute Cocaine Intoxication: Current Methods of Treatment. NIDA Research Monograph Series, Number 123. DHHS Pub. No. (ADM) 93-3498. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 147-155.
Samber, S. Methamphetamine spread creates need for more comprehensive approaches. The NCADI Reporter June 30, 1997. http://www.health.org/pressrel/itn/rep/19.htm [Accessed February 5, 1998].
Satel, S.L.; Southwick, S.M.; and Gawin, F.H. Clinical features of cocaine-induced paranoia. American Journal of Psychiatry. 1991;148(4):495-498. [pmid: 2006696].
Sato, M.; Chen, C.C.; Akiyama, K.; and Otsuki, S. Acute exacerbation of paranoid psychotic state after long-term abstinence in patients with previous methamphetamine psychosis. Biological Psychiatry. 1983;18:429-440.
Scandling, J., and Spital, A. Amphetamine-associated myoblobinuric myoglobinuric renal failure. Southern Medical Journal. 1982;75: 237-240.
Schottenfeld, R.S.; Pakes, J.; Ziedonis, D.; and Kosten, T.R. Buprenorphine: Dose-related effects on cocaine and opioid use in cocaine-abusing opioid-dependent humans. Biological Psychiatry. 1993;34:66-74.
Schrank, K.S. Cocaine-related emergency department presentations. In: Sorer, H., ed. Acute Cocaine Intoxication: Current Methods of Treatment. NIDA Research Monograph Series, Number 123. DHHS Pub. No. (ADM) 93-3498. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 110-128.
Seiden, L.S.; Fischman, M.W.; and Schuster, C.R. Long-term methamphetamine induced changes in brain catecholamines in tolerant rhesus monkeys. Drug and Alcohol Dependence. 1976;1:215-219.
Selden, L.S. Neurotoxicity of methamphetamine: Mechanisms of action and issues related to aging. In: Miller, M.A., and Kozel, N.J., eds. Methamphetamine Abuse: Epidemiologic Issues and Implications. NIDA Research Monograph Series, Number 115. DHHS Pub. No. (ADM) 91-1836. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 24-32.
Self, D., and Nestler, E. Molecular mechanisms of drug reinforcement and addiction. Annual Review of Neuroscience. 1995;18:463-495.
Shaner, A.; Roberts, L.J.; Eckman, T.A.; Tucker, D.E.; Tsuang, J.W.; Wilkens, J.N.; and Mintz, J. Monetary reinforcement of abstinence from cocaine among mentally ill patients with cocaine dependence. Psychiatric Services. 1997;48:807-810.
Shoptaw, S.; Frosch, D.; Rawson, R.A.; and Ling, W. Cocaine abuse counseling as HIV prevention. AIDS Education and Prevention. 1997;9(6):511-20. [pmid: 9451479].
Shoptaw, S.; Rawson, R.A.; McCabb, M.J.; and Obert, J.L. The matrix model of outpatient stimulant abuse treatment: Evidence of efficacy. Journal of Addictive Diseases. 1994;13(4): 129-141.
Siegel, R.K. Cocaine smoking. Journal of Psychoactive Drugs. 1982;14(4):271-359. [pmid: 6765034].
Siegel, R.K. Cocaine smoking: Nature and extent of coca paste and cocaine free-base abuse. In: Washton, A.M., and Gold, M.S., eds. Cocaine: A Clinician's Handbook. New York: Guilford Press, 1987. pp. 175-191.
Silverman, K.; Bigelow, G.E.; and Stitzer, M.L. Treatment of cocaine abuse in methadone maintenance patients. In: Higgins, S.T., and Katz, J.L., eds. Cocaine Abuse: Behavior, Pharmacology, and Clinical Applications. San Diego, CA: Academic Press, 1998.
Silverman, K.; Higgins, S.T.; Brooner, R.K.; Monyoya, I.D.; Cone, E.J.; Schuster, C.R.; and Preston, K.L. Sustained cocaine abstinence in methadone maintenance patients through voucher-based reinforcement therapy. Archives of General Psychiatry. 1996;53:409-415.
Sisson, R., and Azrin, N.H. The community reinforcement approach. In: Hester, R.K., and Miller, W.R., eds. Handbook of Alcoholism Treatment Approaches: Effective Alternatives. New York: Pergamon Press, 1989. pp. 242-258.
Snyder, S. Drugs and the Brain. New York: Scientific American Library, 1986.
Sorensen, J.L. Preventing HIV transmission in drug treatment programs: What works?. Journal of Addictive Diseases. 1991;10(4):67-79. [pmid: 1777500].
Sowder, B., and Beschner, G., eds. "Methamphetamine: An illicit drug with high abuse potential." Unpublished report from NIDA contract no. 271-90-0002. Rockville, MD: T. Head and Company, Inc. 1993.
Spotts, J.V., and Spotts, C.A. Use and Abuse of Amphetamine and Its Substitutes. NIDA Research Issues, No. 25. Rockville, MD: National Institute on Drug Abuse, 1980.
Stanton, M.D., and Shadish, W.R. Outcome, attrition, and family-couples treatment for substance abuse: A meta-analysis and review of the controlled comparative studies. Psychological Bulletin. 1997;122:170-191.
Stapleton, J.M.; Morgan, M.J.; Phillips, R.L.; Wong, D.F.; Yung, B.C.; Shaya, E.K.; Dannals, R.F.; Liu, X.; Grayson, R.L.; and London, E.D. Cerebral glucose utilization in polysubstance abuse. Neuropsychopharmacology. 1995;13(1):21-31. [pmid: 8526968].
Stark, M.J. Dropping out of substance abuse treatment: A clinically oriented review. Clinical Psychology Review. 1992;12:93-116.
Stark, M.J.; Campbell, B.K.; and Brinkerhoff, C.V. "Hello, may we help you?" A study of attrition prevention at the time of the first phone contact with substance-abusing clients. American Journal of Drug and Alcohol Abuse. 1990;16:67-76.
Stitzer, M.L.; Bickel, W.K.; Bigelow, G.E.; and Liebson, I.A. Effects of methadone dose contingencies on urinalysis test results of poly-abusing methadone-maintenance patients. Drug and Alcohol Dependence. 1986;18:341-348.
Stitzer, M.L.; Bigelow, G.E.; and Gross, J. Behavioral treatment of drug abuse. In: Karsu, T.B., ed. American Psychiatric Association Treatment Manual. Washington, DC: American Psychiatric Association, 1989.
Stitzer, M.L., and Higgins, S.T. Behavioral treatment of drug and alcohol abuse. In: Bloom, F.E., and Kupfer, D.J., eds. Psychopharmacology: The Fourth Generation of Progress. New York: Raven Press, 1995. pp. 1807-1819.
Stitzer, M.L.; Iguchi, M.Y.; and Felch, L.J. Contingent take-home incentive: Effects on drug use of methadone maintenance patients. . Journal of Consulting and Clinical Psychology. 1992;60:927-934.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. National Household Survey on Drug Abuse. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1988.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. National Household Survey on Drug Abuse. DHHS Pub. No. (ADM) 89-1636. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1989.
Substance Abuse and Mental Health Services Administration (SAMHSA), National Clearinghouse for Alcohol and Drug Information. 1993 Monitoring the Future Survey: Data Tables and Figures. Washington, DC: U.S. Government Printing Office, 1993a.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. National Household Survey on Drug Abuse. DHHS Pub. No. (SMA) 93-2053. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993b.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. National Household Survey on Drug Abuse. DHHS Pub. No. (SMA) 97-3149. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996a.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. Preliminary Estimates From the Drug Abuse Warning Network. Advance Report No. 17, August, 1996b. http://www.health.org/pubs/dawn/index-htm [Accessed May 6, 1998].
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. Preliminary Results From the 1997 National Household Survey on Drug Abuse. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998. http://www.samhsa.gov/oas/nhsda/nhsda97/httoc.htm [Accessed December 7, 1998].
Tennant, F.S., and Rawson, R.A. Cocaine and amphetamine dependence treated with desipramine. In: Harris, L.S., ed. Problems of Drug Dependence, 1982: Proceedings of the 44th Annual Scientific Meeting, the Committee on Problems of Drug Dependence. NIDA Research Monograph Series, Number 43. NTIS Pub. No. 83-252692. Rockville, MD: National Institute on Drug Abuse, 1983. pp. 351-355.
Tinklenberg, J.R. The treatment of acute amphetamine psychosis. A Treatment Manual for Acute Drug Abuse Emergencies. DHEW Pub. No. (ADM) 76-230. Rockville, MD: Alcohol, Drug Abuse, and Mental Health Administration, 1975.
Trulson, M.E., and Trulson, V.M. Effects of chronic methamphetamine administration on tryptophan hydroxylase activity, [3H]-serotonin synaptosomal uptake, and serotonin metabolism in rat brain following systemic tryptophan loading. Neuropharmacology. 1982a;21:521-527.
Trulson, M.E., and Trulson, V.M. Reduction in brain serotonin synthesis rate following chronic methamphetamine administration in rats. European Journal of Pharmacology. 1982b;83:97-100.
Tusel, D.J.; Piotrowski, N.A.; Sees, K.; Reilly, P.M.; Banys, P.; Meek, P.; and Hall, S.M. Contingency contracting for illicit drug use with opioid addicts in methadone treatment [abstract]. In: Harris, L.S., ed. Problems of Drug Dependence 1994: Proceedings of the 56th Annual Scientific Meeting of the College on Drug Dependence. NIDA Research Monograph Series, Number 153. DHHS Pub. No. (ADM) 95-3883. Rockville, MD: National Institute on Drug Abuse, 1995. p. 155.
Ulm, R.R.; Volpicelli, J.R.; and Volpicelli, L.A. Opiates and alcohol self-administration in animals. Journal of Clinical Psychiatry. 1995;56(suppl. 7):5-14.
van Gorp, W.G.; Altshuler, L.; Theberge, D.C.; Wilkins, J.; Dixon, W. Cognitive impairment in euthymic bipolar patients with and without prior alcohol dependence: A preliminary study. Archives of General Psychiatry. 1998;55(1):41-46. [pmid: 9435759].
Volkow, N.D.; Ding, Y.S.; Fowler, J.S.; and Wang, G.J. Cocaine addiction: Hypothesis derived from imaging studies with PET. Journal of Addictive Diseases. 1996;15:55-71.
Volkow, N.D.; Wang, G.J.; Fischman, M.W.; Foltin, R.W.; Fowler, J.S.; Abumrad, N.N.; Vitkum, S.; Logan, J.; Gatley, S.J.; Pappas, N.; Hitzemann, R.; and Shea, C.E. Relationship between subjective effects of cocaine and dopamine transporter occupancy. Nature. 1997a;386:827-830.
Volkow, N.D.; Wang, G.J.; Fowler, J.S.; Logan, J.; Gatley, S.J.; Hitzemann, R.; Chen, A.D.; Dewey, S.L.; and Pappas, N. Decreased striatal dopaminergic responsiveness in detoxified cocaine-dependent subjects. Nature. 1997b;386:830-833.
Wada, K., and Fukui, S. Relationship between years of methamphetamine use and symptoms of methamphetamine psychosis. Japanese Journal of Alcohol and Drug Dependence. 1990;25:143-158.
Wagner, G.C.; Seiden, L.S.; and Schuster, C.R. Methamphetamine-induced changes in brain catecholamines in rats and guinea pigs. Drug and Alcohol Dependence. 1979;4:435-438.
Wallace, B.C. Treating crack cocaine dependence: The critical role of relapse prevention. Journal of Psychoactive Drugs. 1992;42(2):213-221. [pmid: 1507002].
Ward, A.S.; Haney, M.; Fischman, M.W.; and Foltin, W. Binge cocaine self-administration in humans: Intravenous cocaine. Psychopharmacology. 1997;132:375-381.
Washton, A.M. Preventing relapse to cocaine. Journal of Clinical Psychiatry. 1988;49(suppl. 2):34-38.
Washton, A.M. Cocaine Addiction: Treatment, Recovery, and Relapse Prevention. New York: Norton, 1989.
Washton, A.M. Cocaine Recovery Workbooks: Preventing Relapse. Center City, MN: Hazelden Educational Materials, 1990a.
Washton, A.M. Staying Off Cocaine: Cravings, Other Drugs, and Slips. Center City, MN: Hazelden Foundation, 1990b.
Washton, A.M. Step Zero: Getting to Recovery. New York: HarperCollins, 1991.
Washton, A.M. Outpatient groups at different stages of substance abuse treatment: Preparation, initial abstinence, and relapse prevention. In: Brook, D., and Spitz, H., eds. Group Psychotherapy of Substance Abuse. Washington, DC: American Psychiatric Press, in press.
Washton, A.M., and Stone-Washton, N. Outpatient treatment of cocaine and crack addiction: A clinical perspective. In: Tims, F.M., and Leukefeld, C.G., eds. Cocaine Treatment: Research and Clinical Perspectives. NIDA Research Monograph Series, Number 135. DHHS Pub. No. (ADM) 93-3639. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 15-30.
Weddington, W.W.; Brown, B.S.; Haertzen, C.A.; Hess, J.M.; Mahaffey, J.R.; Kolar, A.F.; and Jaffe, J.H. Comparison of amantadine and desipramine combined with psychotherapy for treatment of cocaine dependence. American Journal of Drug and Alcohol Abuse. 1991;17:137-152.
Weinrieb, R., and O'Brien, C. Persistent cognitive deficits attributed to substance abuse. Neurologic Complications of Drug and Alcohol Abuse (Neurologic Clinics). 1993;11(3):670-675.
Weis, D.A. "Stimulant use disorder (adult)." Unpublished report. Minneapolis, MN: Institute for Healthcare Quality/Health Risk Management. 1997.
Wells, E.A.; Peterson, P.L.; Gainey, R.R.; Hawkins, J.D.; and Catalano, R.F. Outpatient treatment for cocaine abuse: A controlled comparison of relapse prevention and twelve-step approaches. American Journal of Drug and Alcohol Abuse. 1994;20:1-17.
Wesson, D.R., and Smith, D.E. Cocaine: Its use for central nervous system stimulation including recreational and medical use. In: Petersen, R.C., and Stillman, R.C., eds. Cocaine: 1977. NIDA Research Monograph Series, Number 13. DHHS Pub. No. (ADM) 77-432. Rockville, MD: National Institute on Drug Abuse, 1977. pp. 137-152.
West, R., and Gossop, M. Overview: A comparison of withdrawal symptoms from difference different drug classes. Addiction. 1994;89:1483-1489.
Wetli, C.V. The pathology of cocaine: Perspectives from the autopsy table. In: Sorer, H., ed. Acute Cocaine Intoxication: Current Methods of Treatment. NIDA Research Monograph Series, Number 123. DHHS Pub. No. (ADM) 93-3498. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 172-182.
Wise, R.A. Neuroleptics and operant behavior: The anhedonia hypothesis. Behavioral and Brain Science. 1982;5:39-87.
Wise, R.A. Neurobiology of addiction. Current Opinions in Neurobiology. 1996;6:243-251.
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. Psychotherapy in community methadone programs: A validation study. American Journal of Psychiatry. 1995;152:1302-1308.
Woolverton, W.L.; Ricuarte, Ricaurte, G.A.; Forno, L.S.; and Seiden, L.S. Long-term effects of [chronic] methamphetamine administration in rhesus monkeys. Brain Research. 1989;486:73-78.
Yamamura, T.; Hishida, S.; Hatake, K.; Taniguchi, T.; and Ouchi, H. Effects of methamphetamine and ethanol on learning and brain neurotransmitters in rats. Pharmacological and Biochemical Behaviors. 1992;42(3):389-400.