# Appendices

Appendix A—Bibliography

Appendix B—Client Worksheets

Appendix C --Screening Tests for Cognitive Impairments

Appendix D—Glossary

Appendix E --Resource Panel

Appendix F --Field Reviewers