# Consensus Panel

1997-98 Revision Consensus Panel Chair
- Ken C. Winters, Ph.D.
- Associate Professor
- Department of Psychiatry
- University of Minnesota Hospital and Clinic
- Minneapolis, Minnesota

1997-98 Revision Consensus Panel
- Gayle A. Dakof, Ph.D.
- Research Assistant Professor
- Center for Family Studies
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- Miami, Florida
- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida
- Nancy Jainchill, Ph.D.
- Senior Principal Investigator
- Center for Therapeutic Community Research
- National Development and Research Institutes
- New York, New York
- Michele D. Kipke, Ph.D.
- Director
- Board on Children, Youth, and Families
- National Research Council
- Institute of Medicine
- Washington, D.C.
- John R. Knight, M.D.
- Associate Director for Medical Education
- Division on Addictions
- Harvard Medical School
- Assistant in Medicine
- Children's Hospital
- Boston, Massachusetts
- Howard Liddle, Ed.D.
- Professor and Director
- Center for Treatment Research on Adolescent Drug Abuse
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- Miami, Florida

1992-93 Consensus Panel Chair
- S. Kenneth Schonberg
- Director
- Division of Adolescent Medicine
- Montefiore Medical Center
- Bronx, New York

1992-93 Workgroup Leaders
- Gerald D. Shulman
- Executive Director
- Mountain Wood Treatment Center
- Charlottesville, Virginia
- Susan Wallace
- Caritas House
- Pawtucket, Rhode Island
- Ken C. Winters, Ph.D.
- Director
- Center for Adolescent Substance Abuse
- University of Minnesota,
- Division of Adolescent Health
- Minneapolis, Minnesota
- John Zachariah
- Regional Administrator
- American Correctional Association
- Laurel, Maryland

1992-93 Workgroup Members
- Bruce Abel, D.S.W., L.C.S.W.
- Looking Glass Counseling Center
- Eugene, Oregon
- Drew Alexander, M.D.
- Adolescent Health
- Dallas, Texas
- Terry Beartusk
- Executive Director
- Thunder Child Treatment Center
- Sheridan, Wyoming
- Cherrie Boyer, Ph.D.
- Department of Pediatrics
- University of California
- San Francisco, California
- Peter Cohen, M.D.
- Medical Director
- Children and Adolescents Programs
- Rockville, Maryland
- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida
- Elizabeth Cannon Duncan
- South Carolina Commission on Alcohol and Drug Abuse Treatment
- Columbia, South Carolina
- Gary Giron
- Executive Director
- La Neuve Vida
- Santa Fe, New Mexico
- Raymond L. Hilton, Ed.D.
- Assistant Superintendent
- Department of Children and Youth Services
- Long Lane School
- Middleton, Connecticut
- Mary Jane Salsbery, R.N., C.C.D.N.
- Johnson County Adolescent Center for Treatment
- Olathe, Kansas
- Barbara Zugor
- Executive Director
- TASC, Inc.
- Phoenix, Arizona