# Appendix C --Field Reviewers

- Jack Araza, Ph.D., C.A.D.C.
- Carson City, Nevada

- Michael Beard
- Deputy Director
- Lassen County Alcohol and Drug Abuse Department
- Susanville, California

- Helen Bergman, M.S.W., L.I.C.S.W.
- Co-Director
- Community Connections
- Washington, D.C.

- Robert Bick, M.A., S.A.C.
- Director
- Champlain Drug and Alcohol Services
- Howard Center for Human Services
- South Burlington, Vermont

- Saroja A. Boaz, M.S., A.C.C.
- Executive Director
- Intake Assessment and Referral Center
- Flint, Michigan

- Patricia Bradford, L.I.S.W., L.M.F.T., C.T.S.
- P.A. Bradford and Associates
- Columbia, South Carolina

- Deborah Briseno, M.S.Ed., C.A.D.C.
- Program Director
- Central East Alcoholism and Drug Council
- Mattoon, Illinois

- Margaret K. Brooks, Esq.
- Consultant
- Montclair, New Jersey

- Richard Conlon, M.P.A.
- Assistant Chief
- Behavioral Interventions and Research Branch
- Division of STD Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Patricia Cummings, M.S.S.W., L.C.S.W.
- Prevention Director/Planning Officer
- Seven Counties Services, Inc.
- Louisville, Kentucky

- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

- John de Miranda, Ed.M.
- Executive Director
- National Association on Alcohol, Drugs, and Disability, Inc.
- San Mateo, California

- Jean Anne Donaldson, M.A.
- Public Health Advisor
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Janice M. Dyehouse, R.N., M.S.N., Ph.D.
- Professor
- College of Nursing
- University of Cincinnati
- Cincinnati, Ohio

- Bryan R. Ellis, M.A., C.S.W.
- President
- ADE Incorporated
- Clarkston, Michigan

- Janice Embree-Bever, M.A., C.A.C.-III
- Planning/Grants Officer III
- Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado

- Jill Shepard Erickson, M.S.W.
- Public Health Advisor
- Child and Family Branch
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- David L. Favreau, L.M.H.C., C.A.S.
- Assertive Communications
- Dracut, Massachusetts

- Jerry P. Flanzer, D.S.W.
- Director
- Recovery and Family Treatment, Inc.
- Alexandria, Virginia

- Luis E. Flores, M.A.
- Associate Administrator
- Stop Child Abuse and Neglect, Inc.
- Laredo, Texas

- Lawrence S. Friedman, M.D.
- Chief
- Division of Primary Care Pediatrics and Adolescent Medicine
- University of California at San Diego
- San Diego, California

- Michael F. Goodnow, C.A.D.A.C., I.C.A.D.A.C.
- Social Science Program Specialist
- Training & Technical Assistance Division
- Office of Juvenile Justice and Delinquency Prevention
- Department of Justice
- Washington, D.C.

- Don M. Hashimoto, Psy.D.
- Clinical Director
- Ohana Counseling Services, Inc.
- Hilo, Hawaii

- Martin Hernandez
- Ventura County Behavioral Health Department
- Ventura, California

- James Herrera, M.A., L.P.C.C.
- Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- Norman G. Hoffmann, Ph.D.
- Director, Policy Program
- Center for Alcohol and Addiction Studies
- Department of Community Health
- Brown University
- Providence, Rhode Island

- Lewis Jay Lester, M.S.W., L.C.S.W.
- Eureka, California

- Victor Lidz, Ph.D.
- Assistant Professor
- Institute for Addictive Disorders
- Allegheny University of Health Sciences
- Philadelphia, Pennsylvania

- Colleen R. McLaughlin, Ph.D.
- Senior Research Analyst
- Department of Surgery
- Medical College of Virginia
- Richmond, Virginia

- Thomas J. McMahon, Ph.D.
- Assistant Professor of Psychology
- Yale School of Medicine
- Substance Abuse Center
- New Haven, Connecticut

- Lisa A. Melchior, Ph.D.
- Vice President for Evaluation
- The Measurement Group
- Culver City, California

- D. Paul Moberg, Ph.D.
- Center for Health Policy and Program Evaluation
- University of Wisconsin at Madison
- Madison, Wisconsin

- Andrew Morral
- RAND
- Santa Monica, California

- David F. O'Connell, Ph.D.
- Corporate Clinical Director
- Adolescent Treatment Services
- Caron Foundation
- Wernersville, Pennsylvania

- Nancy Petry, Ph.D.
- Assistant Professor
- Department of Psychiatry
- University of Connecticut Health Center
- Farmington, Connecticut

- Elizabeth Rahdert, Ph.D.
- Research Psychologist
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Scott M. Reiner, M.S., C.A.C., C.C.S.
- Substance Abuse Program Supervisor
- Substance Abuse Services Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- Jeanine Ricchetti, M.S., L.P.C., C.C.A.S.
- Clinician/Clinical Supervisor
- Wayne County Mental Health
- Goldsboro, North Carolina

- Steve Riedel, M.S.Ed.
- Associate Director
- Our Home, Inc.
- Huron, South Dakota

- D. Paul Robinson, M.D.
- Division of Adolescent Medicine
- Children's Hospital of Missouri
- Columbia, Missouri

- Peter B. Rockholz, M.S.S.W.
- Director
- Residential Services
- APT Foundation, Inc.
- Newtown, Connecticut

- Sarah E. Shapleigh, M.S.W., C.A.P.C.
- Counselor
- Chemical Dependency Services Department
- Grasmere Intermediate Care Facility for the Mentally Ill
- Chicago, Illinois

- Peg J. Shea, M.S.S.W., L.C.S.W., C.C.D.C.
- Program Director
- Turning Point Addiction Services
- Missoula, Montana

- Lawrence M. Sideman, Ph.D.
- Clinical Director/Assistant Director
- Treatment Assessment Screening Center, Inc.
- Phoenix, Arizona

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- James Taylor, M.A., C.A.D.C. II
- Alcohol and Drug Treatment Coordinator
- Hillcrest Youth Correctional Facility
- Salem, Oregon

- Sally Towns, M.Ed., M.S.W.
- Mental Health Specialist
- Louisiana Office of Mental Health
- Baton Rouge, Louisiana

- William L. White
- Senior Research Consultant
- Lighthouse Institute
- Chestnut Health Systems, Inc.
- Bloomington, Illinois

- Raymond E. Wilson, M.A., C.A.D.C., M.S.
- Senior Counselor, M.H.S.-II
- Drug Treatment Programs
- Marion County Health Department
- Salem, Oregon

- Katherine Wingfield, M.S.W.
- Program Manager
- Chemical Dependency Initiative
- Child Welfare League of America
- Washington, D.C.