# Appendix B —Medical Management of Drug Intoxication and Withdrawal

The following table was created by Dr. John Knight and reprinted with his permission. It will appear in the forthcoming publication, Knight, J.R. Substance use, abuse, and dependence. In: Levine, M.D.; Carey, W.B.; and Crocker, A.C., eds. Developmental-Behavioral Pediatrics, 3rd edition. Philadelphia: W.B. Saunders, in press.

A. Alcohol

A. Alcohol

A. Alcohol
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Beer Wine Hard Liquor | Mild-Mod: lower level of consciousness, poor coordination, ataxia, nystagmus, conjunctival injection, slurred speech, stupor, GI bleed, orthostatic hypotension | Observation and supportive care, protect airway, position on side to avoid aspiration | Mild-Mod: restlessness, agitation, coarse tremor, higher sensitivity to sensory input, nausea, vomiting, anorexia, autonomic hyperactivity (tachycardia, hypertension, hyperthermia), anxiety/depression, headache, insomnia | Thiamine 100 mg. IM, Benzodiazepine taper (chlordiazepoxide 25-50 mg. q6h X 24 hrs., then 25 mg. q6h X 48 hrs.; or diazepam, clonazepam, oxazepam), Multivitamins
| Severe: Respiratory depression, coma, death. (Chronic: pancreatitis, cirrhosis, are rare in adolescents) | Ventilatory support, intensive care | Severe: seizures, hallucinations, delirium, death | Seizures: benzodiazepines (diazepam 0.2-0.5 mg/kg/dose IV., Max. dose=10 mg., or 0.5 mg/kg/dose PR) Hallucinations: Haloperidol
| Pathological: belligerent, excited, combative, psychotic state (even after small amount in susceptible person) | Physical restraint, low dose benzodiazepine (lorazepam 1-5 mg. PO as needed), or haloperidol 1-5 mg. q4-8 hrs. IM or 1-15 mg/dose PO
Miscellaneous Information: Alcohol is highly addictive, and withdrawal from it is associated with serious, potentially lethal, side effects which begin 6-24 hours after the last drink. Alcohol dependency is rare in adolescents, however, but alcohol-related deaths are not. Adolescents tend to be binge drinkers and are at high risk for alcohol-related accidents and acute alcohol poisoning.

B. Cannabis

B. Cannabis

B. Cannabis
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Marijuana Pot, herb, grass, weed, reefer, dope, Buds, sinsemilla, Thai sticksTHC capsules Hashish Hashish Oil | Acute: Euphoria, sensory stimulation, pupillary constriction, conjunctival injection, photophobia, nystagmus, diplopia, greater appetite, autonomic dysfunction (tachycardia, hypertension, orthostatic hypotension) temporary bronchodilatation | Reassurance and observation
| Chronic: gynecomastia, reactive airway disease,lower sperm count, weight gain, lethargy, amotivational syndrome | Discontinuation of use, symptomatic treatment/care (bronchodilators for wheezing) | Chronic users: mild irritability, agitation, insomnia, EEG changes. | Reassurance; symptoms disappear in 3-4 days
| Pathological: panic, delirium, psychosis, flashbacks | Psychosis: Neuroleptic medication
Miscellaneous Information: Cannabis derivatives have relatively low addictive potential. These drugs are commonly used by adolescents, however, and are associated with adverse psychological effects. The potency of marijuana has tripled over the past 25 years.

C. Hallucinogens

C. Hallucinogens

C. Hallucinogens
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Phencyclidine (PCP) angel dust, super grass, peace weed Lysergic acid diethylamide (LSD) Acid, blotters, orange sunshine, blue heaven, microdot, sugar cubes Mescaline mesc Peyote buttons, cactus Psilocybin magic mushrooms, 'shrooms Jimson weed locoweed Nightshade | Acute: Perceptual (visual, auditory) distortion and hallucinations, nystagmus, feelings of depersonaliza-tion, mild nausea, tremors, tachycardia, hypertension, hyperreflexia Chronic: flashbacks Pathological: panic, paranoia, psychosis | Reassurance and observation (For anticholinergics, i.e., jimson weed, nightshade, symptoms are more severe and may require gastric lavage, benzodiazepine sedation, and hospitalization.) Discontinuation of use Psychosis: close observation in a quiet room. benzodiazepines (Lorazepam 1-5 mg. PO). Use of neuroleptic medication is controversial. | Psychological | Reassurance
Miscellaneous Information: PCP may be sprinkled on marijuana and smoked. Exposure can thus occur without the user's knowledge.

D. Inhalants

D. Inhalants

D. Inhalants
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Nitrous Oxide, laughing gas, whippets Amyl Nitrite, poppers, snappers Butyl Nitrate, rush, bullet, climax Chlorohydrocarbons aerosol spray cans Hydrocarbons, gasoline, glue, solvents, White-out (typewriter correction fluid) Leaded Gasoline (not in US) | Acute: euphoria, disorientation, sedation, conjunctival injection, acute toxicity to CNS, liver, kidneys Nitrates: sudden hypoxemia, hypotension Chronic: peripheral nerve, CNS, liver, and kidney damage Pathological: cardiac arrhythmia and arrest | Symptomatic medical treatments Discontinuation of use, supportive therapies (dialysis, etc.) Plumbism: Chelation therapy Resuscitation, hospitalization | Psychological Physiological-unknown | Reassurance, support
Miscellaneous Information: Nitrous oxide is sometimes sold at rock concerts inside balloons. Nitrate compounds have been most popular among gay men, allegedly to enhance sexual experiences. The volatile hydrocarbon compounds are favored by younger adolescents and popular in some Latin-American countries, on Native American reservations, and in Latino communities within the United States.

E. Stimulants

E. Stimulants

E. Stimulants
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Cocaine Coke, Snow, Flake, Blow, Nose Candy Crack Freebase, Rocks Amphetamines Speed, Black Beauties Methamphetamine Crank, Crystal Meth, Ice Methylphenidate Ritalin Pemoline Cylert Rx Diet Pills Didrex, Tenuate, Ionamin, Sanorex, etc. "Legal speed" OTC diet or stay awake pills | Acute: exhilaration, euphoria, restlessness, irritability, insomnia, pupillary dilatation, tachycardia, arrhythmia, chest pain, hypertension, anorexia, hyperpyrexia, hyperreflexia Chronic: (if snorting: inflamed nasal mucosa, septal erosion or perforation) confusion, sensory hallucinations, paranoia, depression Pathological: sudden cardiac arrest, hypertensive crisis, seizures | Reassurance and observation Symptomatic care Agitation: high dose benzodiazepines (Diazepam 10-25 mg) Tachycardia, HTN: (controversial, see below) Hyperthermia: external cooling Discontinuation of use, symptomatic treatment/care. Psychosis: Neuroleptic medication Resuscitation, hospitalization HTN crisis: beta-blockers, Phentolamine, Nitroprusside Seizures: IV Diazepam, (see alcohol section above), or Phenytoin 15-20 mg/kg slow IV push with cardiac monitor | Chronic users: severe depression with suicidal/homicidal ideation, exhaustion, prolonged sleep, voracious appetite | Close observation, reassurance; symptoms disappear in 3-4 days
Miscellaneous Information: While use of cocaine and crack has declined somewhat in recent years, amphetamines have become more popular. Methamphetamine is more commonly available in California, the West, and Southwest. With the increased public awareness of AD/HD and the popularity of stimulant medications to treat it, Ritalin has now become a drug of abuse among some adolescents. It can be ground up and "snorted," and has been implicated in several reports of sudden cardiac arrest and death. So-called "legal speed," OTC preparations which are available in pharmacies and through mail order houses, can cause toxicity similar to more potent stimulants when taken in high doses.

F. Depressants

F. Depressants

F. Depressants
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Benzodiapines: Valium, "V's," Librium, Serax, Klonopin, Tranxene, Xanax, Halcion, Rohypnol, "Ruffies" Barbiturates: Nembutal, Seconal, Amytal, Tuinal, downers, barbs, blue devils, red devils, yellows, yellow jackets Methaqualone: Quaaludes, ludes, sopors | Mild-Mod: CNS sedation, pupillary constriction, disorientation, slurred speech, staggering gait Severe: Respiratory depression, hypothermia, coma, death Pathological: paradoxical disinhibition, hyperexcitability | Observation and supportive care, protect airway, position on side to avoid aspiration Acute OD: Gastric lavage. Supportive: ventilator, warming blanket, ICU care Symptoms pass in a matter of hours; physical restraint, low dose benzodiazepine rarely needed | Mild-Mod: restlessness, anxiety, agitation, tremor, abdominal cramps, nausea, vomiting, hyperreflexia, hypertension, headache, insomnia Severe: seizures, delirium, hyperpyrexia, hallucinations, death | Gradual reduction of the drug of dependency, or Phenobarbital substitution (calculate phenobarbital equivalent of daily dose, or give 3-4 mg/kg/day divided by q8h) with gradual taper. Or change short-acting benzodiazepine to longer-acting benzodiazepine and then taper Seizures: Diazepam Hallucinations: Haloperidol (see alcohol section above for doses)
Miscellaneous Information: These compounds are all similar to alcohol in effect and highly addictive. Withdrawal symptoms are severe and may begin 12-16 hours after last dose or may be delayed for up to a week.

G. Narcotics

G. Narcotics

G. Narcotics
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Heroin, smack, horse, junk, brown sugar, Big H, mud Opium Rx Narcotics Morphine, Meperidine Fentanyl, Oxycodone, Hydrocodone, Codeine Darvon, etc. | Acute: Euphoria, pupillary constriction, depression of respirations and gag reflex, bradycardia, hypotension, constipation Chronic: complications of IV use include Hepatitis B, HIV/AIDS, SBE, brain abscesses Pathological: Acute OD may cause respiratory arrest and death | Airway protection, judicious use of naloxone Discontinuation of use, targeted medical care for infectious complications Intubation and ventilation, naloxone (IV, IM, SC, ETT): children < 20 kg: 0.1 mg/kg/dose q2-3 hrs. children > 20 kg: 2-5 mg/dose | Chronic users: restlessness, lacrimation, yawning, pupillary dilatation, rhinorrhea, sniffing, sneezing, sweating, flushing, tachycardia, hypertension, muscle cramps, abdominal cramps, nausea, vomiting, diarrhea | Acute detoxification: Methadone (PO) Children: 0.7 mg/kg/day divided by q4-6 hrs., or adult 30-40 mg./ day in 3-4 divided doses, with 5 mg/day taper. Clonidine (PO) Children: 5-7 mcg/kg/day divided by q6-12 hrs. (max = 0.9 mg/day) Adult: 0.1 mg. test dose, check postural BPs. If stable, 0.1-0.2 mg PO q4-6 hrs. Long-term treatment: Long-term therapeutic support. Methadone or LAAM maintenance (specialized clinics only)
Miscellaneous Information: Individuals who abuse narcotics seldom seek treatment for intoxication. They are more often found semi-comatose and brought to the hospital by friends or the EMS for treatment. When treating an overdose, remember that naloxone has a shorter duration of action than most narcotic drugs, and doses therefore should be repeated at fairly frequent intervals. These patients require lengthy (12-24 hours) periods of observation in hospital.

H. Designer Drugs

H. Designer Drugs

H. Designer Drugs
Names/Preparations | Intoxication | | Withdrawal
| Signs and Symptoms | Treatment | Signs and Symptoms | Treatment
Fentanyl analogs Synthetic heroin, China White Meperidine analogs MPPP, MPTP | Similar to narcotics (above) | Similar to narcotics (above) | Similar to narcotics (above) | Similar to narcotics (above)
Amphetamine analogs MDMA, Ecstasy, Adam, EVE, STP, PMA, TMA, DOM, DOB, etc. | Similar to amphetamines (above) | Similar to amphetamines (above) | Similar to amphetamines (above) | Similar to amphetamines (above)
PCP Analogs PCPy, PCE | Similar to PCP (above) | Similar to PCP (above) | Similar to PCP (above) | Similar to PCP (above)
Miscellaneous Information: More popular on the West Coast, designer drugs can be both stronger and cheaper than the parent compound. Quality is not controlled during illicit manufacturing, posing great danger to users. For example: MPTP, a contaminant of the Meperidine analog MPPP, causes irreversible Parkinson's Disease.

## Source

Knight J.R.,Developmental-Behavioral Pediatrics,

## References

Chang G., Kosten T.R.Substance Abuse: A Comprehensive Textbook
Center for Substance Abuse Treatment.Guidelines for the Treatment of Alcohol- and Other Drug-Abusing Adolescents
Center for Substance Abuse Treatment.Detoxification for Alcohol and Other Drugs
Barone, M.A., ed.The Harriet Lane Handbook,

## Acknowledgment:

Michael Shannon, M.D., M.P.H. (Toxicology Program) and Brigid Vaughan, M.D. (Department of Psychiatry) at Children's Hospital, Boston, assisted with preparation of this table.