# Appendix A -- Bibliography

Alcoholics Anonymous. Alcoholics Anonymous: The Story of How Many Thousands of Men and Women Have Recovered From Alcoholism, 3rd ed. New York: Alcoholics Anonymous World Services, 1976.
Alexander, J.F., and Parsons, B.V. Short-term behavioral intervention with delinquent families: Impact on process and relativist. Journal of Abnormal Psychology. 1973;81: 219-225.
Alford, G. S.; Koehler, R.A.; and Leonard, J. Alcoholics Anonymous-Narcotics Anonymous model inpatient treatment of chemically dependent adolescents: A 2-year outcome study. Journal of Studies on Alcohol. 1991;52:118-126.
American Academy of Pediatrics. The Classification of Child and Adolescent Mental Diagnoses in Primary Care: Diagnostic and Statistical Manual for Primary Care (DSM-PC) Child and Adolescent Version. Elk Grove Village, IL: American Academy of Pediatrics. 1996.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC: American Psychiatric Press. 1994.
Anderson, D.J. Perspectives on Treatment: The Minnesota Experience. Center City, MN: Hazelden Foundation. 1981.
Bass, D. Helping Vulnerable Youths: Runaway and Homeless Adolescents in the United States. Washington, DC: National Association of Social Workers Press. 1992.
Baumrind, D., and Moselle, K.A. A development perspective on adolescent drug abuse. Advances in Alcohol and Substance Abuse. 1985;4:41-67.
Beck, A.T.; Wright, F.D.; Newman, C.F.; and Liese, B.S. Cognitive Therapy of Substance Abuse. New York: Guilford Press. 1993.
Berg, I.K. Family Preservation: A Brief Therapy Workbook. London: B.T. Press. 1991.
Berg, I.K., and Miller, S. Working With the Problem Drinker: A Solution-Focused Approach. New York: Norton. 1992.
Biederman, J.; Wilens, T.; Mick, E.; Milberger, S.; Spencer, T.J.; and Faraone, S.V. Psychoactive substance use disorders in adults with attention deficit hyperactivity disorder (AD/HD): Effects of AD/HD and psychiatric comorbidity. American Journal of Psychiatry. 1995;152:1652-1658.
Brown, S.A. Recovery patterns in adolescent substance abuse. In: Baer, J.S.; Marlatt, G.A.; and McMahon, R.J., eds. Addictive Behaviors Across the Life Span. London: Sage Publications, 1993. pp. 161-183.
Brown, S.A.; Vik, P.W.; and Creamer, V.A. Characteristics of relapse following adolescent substance abuse treatment. Addictive Behaviors. 1989;14:291-300.
Bukstein, O. Practice parameters for the assessment and treatment of children and adolescents with substance use disorders. Journal of the American Academy of Child and Adolescent Psychiatry. 1997;36(10 Suppl): 140s-156s.
Bukstein, O. Treatment of adolescent alcohol abuse and dependence. Alcohol Health and Research World. 1994;18:296-301.
Bukstein, O. Adolescent Substance Abuse: Assessment, Prevention, and Treatment. New York: John Wiley and Sons. 1995.
Cabaj, R.P. AIDS and chemical dependency: Special issues and treatment barriers for gay and bisexual men. Journal of Psychoactive Drugs. 1989;21(4):387-393. [pmid: 2621509].
Cantwell, D.P. Attention deficit disorder: A review of the past 10 years. Journal of the American Academy of Child and Adolescent Psychiatry. 1996;35:978-987.
Catalano, R.F.; Hawkins, J.D.; Wells, E.A.; Miller, J.M.; and Brewer, D. Evaluation of the effectiveness of adolescent drug abuse treatment, assessment of risks for relapse, and promising approaches for relapse prevention. International Journal of the Addictions. 1990-1991;25:1085-1140.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 9. DHHS Pub. No. (SMA) 95-3061. Washington, DC: U.S. Government Printing Office. 1994.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 14. DHHS Pub. No. (SMA) 95-3031. Washington, DC: U.S. Government Printing Office. 1995a.
Center for Substance Abuse Treatment. Alcohol and Other Drug Screening of Hospitalized Trauma Patients. Treatment Improvement Protocol (TIP) Series, Number 16. DHHS Pub. No. (SMA) 95-3041. Washington, DC: U.S. Government Printing Office. 1995b.
Center for Substance Abuse Treatment. Detoxification from Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series, Number 19. DHHS Pub. No. (SMA) 95-3046. Washington, DC: U.S. Government Printing Office. 1995c.
Center for Substance Abuse Treatment. Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series, Number 21. DHHS Pub. No. (SMA) 95-3051. Washington, DC: U.S. Government Printing Office. 1995d.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, Number 23. DHHS Pub. No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office. 1996.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Physicians. Treatment Improvement Protocol (TIP) Series, Number 24. DHHS Pub. No. (SMA) 97-3139. Washington, DC: U.S. Government Printing Office. 1997.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series, Number 29. DHHS Pub. No. (SMA) 98-3249. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment. Screening and Assessing Adolescents for Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 31. DHHS Pub. No. (SMA) 99-3282. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Brief Interventions and Brief Therapies for Substance Use Disorder Treatment. Treatment Improvement Protocol (TIP) Series. Washington, DC: U.S. Government Printing Office, in press.
Center for Substance Abuse Treatment. Responding to Child Abuse and Neglect Issues of Adult Survivors in Substance Use Disorder Treatment. Treatment Improvement Protocol (TIP) Series. Washington, DC: U.S. Government Printing Office, in press.
Center for Substance Abuse Treatment. Treatment of Persons With HIV/AIDS and Substance Use Disorders. Treatment Improvement Protocol (TIP) Series. Washington, DC: U.S. Government Printing Office, in press.
Centers for Disease Control and Prevention. Premarital sexual experience among adolescent women-United States, 1970-1988. Morbidity and Mortality Weekly Report. 1991;39:929-932.
Centers for Disease Control and Prevention. Pregnancy, Sexually Transmitted Diseases, and Related Risk Behaviors Among U.S. Adolescents. Adolescent Health: State of the Nation Monograph Series, No. 2. CDC Pub. No. 099-4630. Atlanta: CDC. 1994.
Centers for Disease Control and Prevention. Youth risk behavior surveillance-United States, 1995. Morbidity and Mortality Weekly Report. 1996;45(No. SS-4):1-86.
Centers for Disease Control and Prevention. Division of Adolescent and School Health. http://www.cdc/ncdphp/dash/problem.htm. [Accessed August 1997.].
Centers for Disease Control and Prevention. Leading Causes of Mortality and Morbidity and Contributing Behaviors in the United States. 1998. http://www.cdc.gov/nccdphp/dash/ahsumm/ussumm.htm [Accessed August 31, 1998.].
Children's Defense Fund. The Adolescent and Young Adult Fact Book. Washington, DC: Children's Defense Fund. 1991.
Cohen, P.; Cohen, J.; Kasen, S.; Velez, C.N.; Hartmark, C.; Johnson, J.; Rojas, M.; Brook, J.; and Streuning, E. An epidemiological study of disorders in late childhood and adolescence: I. Age- and gender-specific prevalence. Journal of Child Psychology and Psychiatry. 1993;34:851-867.
Colorado Department of Public Health and Environment. Adolescent Health in Colorado, 1997. Report and Recommendations of the Advisory Council on Adolescent Health, February. 1998.
Comfort, M., and Shirley, T.E. Family treatment for homeless alcohol/drug-addicted women and their preschool children. Alcohol Treatment Quarterly. 1990;7(21):129-147.
Cotton, N.S. The familial incidence of alcoholism: A review. Journal of Studies on Alcohol. 1979;40:89B116.
Crowley, T.J., and Riggs, P.D. Adolescent substance use disorder with conduct disorder and comorbid conditions. In: Rahdert, E., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. National Institute on Drug Abuse (NIDA) Research Monograph Series, Number 156. Rockville, MD: National Institute on Drug Abuse, 1995. pp. 49-111.
De Leon, G. The therapeutic community: Status and evolution. International Journal of the Addictions. 1985;20(6-7):823-844.
De Leon, G. The therapeutic community perspective and approach for adolescent substance abusers. In: Feinstein, S.C.; Esman, A.H.; Looney, J.G.; Orvin, G.H.; Schimel, J.L.; Schwartzenberg, A.Z.; and Sorosky, A.D., eds. Adolescent Psychiatry-Development and Clinical Studies. Vol. 15. Chicago: University of Chicago Press, 1988.
De Leon, G. The therapeutic community: Toward a general theory and model. In: Tims, F.; De Leon, G.; and Jainchill, N., eds. Therapeutic Community: Advances in Research and Application. NIDA Research Monograph Series, Number 144. DHHS Pub. No. (ADM) 94-3633. Rockville, MD: National Institute on Drug Abuse, 1994. pp. 16-53.
De Leon, G. Adolescent substance abusers in the therapeutic community: Treatment outcomes. In: Acapora, A., and Nebelkopf, E., eds. Proceedings of the Ninth World Conference on Therapeutic Communities. San Francisco: Abacus, 1995a. pp. 195-201.
De Leon, G. Therapeutic communities for addictions: A theoretical framework. International Journal of the Addictions. 1995b;30(12):1603B1645.
Dembo, R. Problems among youths entering the juvenile justice system, their service needs, and innovative approaches to address them. Substance Use and Misuse. 1996;31(1):81-94. [pmid: 8838394].
Dembo, R.; Williams, L.; Schmeidler, J.; Wish, E.D.; Getreu, A.; and Berry, E. Juvenile crime and drug abuse: A prospective study of high risk youth. Journal of Addictive Diseases. 1991;11:5-31.
Diamond, G.S., and Liddle, H.A. Resolving a therapeutic impasse between parents and adolescents in multidimensional family therapy. Journal of Consulting and Clinical Psychology. 1996;64(3):481-488. [pmid: 8698940].
Diamond, G.M., and Liddle, H.A. "Improving initially poor therapist-adolescent therapeutic alliances: A process study." Paper presented at the Society for Psychotherapy Research Meeting, Santa Fe, NM, 1997.
DiClemente, C. The emergence of adolescents as a risk group for human immunodeficiency virus infection. Journal of Adolescent Research. 1990;5:7-17.
Drug Abuse Warning Network (DAWN). Preliminary Estimates From the Drug Abuse Warning Network. Advance Report No. 17, August. 1996.
Drug Court Clearinghouse and Technical Assistance Project. Juvenile Drug Courts: Preliminary Report. Washington, DC: American University. 1997.
Dryfoos, J.G. Adolescents at Risk: Prevalence and Prevention. New York: Oxford University Press. 1990.
DuRant, R.H.; Escobedo, L.G.; and Heath, G.W. Anabolic-steroid use, strength training, and multiple drug use among adolescents in the United States. Pediatrics. 1995a;96:23-28.
DuRant, R.H.; Getts, A.; Linder, C.W.; McCloud, K.; Treiber, F.; and Woods, E.R. Intentions to use violence to resolve conflict among young adolescents. Journal of Adolescent Health. 1995b;16:128.
Elster, A.B., and Kuznets, N.J., eds. AMA Guidelines for Adolescent Preventive Services (GAPS). Baltimore: Williams & Wilkins. 1994.
Farrell, A.D., and Danish, S.J. Peer drug associations and emotional restraint: Causes and consequences of adolescent drug use?. Journal of Consulting and Clinical Psychology. 1993;61:327-334.
Figley, C.R., and Nelson, T.S. Basic family therapy skills, II: Structural family therapy. Journal of Marital and Family Therapy. 1990;16:225-239.
Forrest, J.D. Timing of reproductive life stages. Obstetrics and Gynecology. 1993;82(1):105-111. [pmid: 8515907].
Friedman, A.S.; Glickman, N.; and Utada, A. Does drug and alcohol use lead to failure to graduate from high school?. Journal of Drug Education. 1985;15:353-364.
Friedman, A.S.; Glickman, N.; and Morrissey, M. Prediction to successful treatment outcome by client characteristics and retention in treatment in adolescent drug treatment programs: A large-scale cross validation study. Journal of Drug Education. 1986;16:149-165.
Friedman, A.S.; Grankik, S.; and Kreisher, C. Motivation for adolescent drug abusers for help and treatment. Journal of Child and Adolescent Substance Abuse. 1994;3:69-88.
Gallant, D.M. Alcoholism: A Guide to Diagnoses, Intervention, and Treatment. New York: Norton. 1988.
Gladding, S.T. Family Therapy: History, Theory, and Practice. Englewood Cliffs, NJ: Merrill. 1995.
Green, M., ed. Bright Futures: Guidelines for Health Supervision of Infants, Children, and Adolescents. Arlington, VA: National Center for Education in Maternal and Child Health. 1994.
Gross, J., and McCaul, M.E. A comparison of drug use and adjustment in urban adolescent children of substance abusers. International Journal of the Addictions. 1990-1991;25:495-511.
Gurman, A.S., and Kniskern, D.P. The future of marital and family therapy. Psychotherapy. 1992;29:65-71.
Gurman, A.S.; Kniskern, D.P.; and Pinsof, W.M. Research on the process and outcome of marital and family therapy. In: Garfield, S.L., and Begin, A.E., eds. Handbook of Psychotherapy and Behavior Change, 2nd ed. New York: John Wiley and Sons, 1986. pp. 565-624.
Hansell, S., and White, H.R. Adolescent drug use, psychological distress, and physical symptoms. Journal of Health and Social Behavior. 1991;32(2):288-301. [pmid: 1940211].
Harrison, P.A., and Fulkerson, J. Minnesota Student Survey-1995: Prevalence of Psychoactive Substance Use Disorders. St. Paul, MN: Department of Human Services. 1996.
Harrison, P.A., and Hoffmann, N. CATOR Report: Adolescent Treatment Completers One Year Later. St. Paul, MN: CATOR. 1989.
Havighurst, R.J. Nurturing the cognitive skills in health. Journal of School Health. 1972;42(2):73-76. [pmid: 4480957].
Hawkins, J.D.; Catalano, R.F.; and Miller, J.Y. Risk and protective factors for alcohol and other drug problems in adolescence and early adulthood: Implications for substance abuse prevention. Psychological Bulletin. 1992;6:73-97.
Hawkins J.D., and Fitzgibbon, J.J. Risk factors and risk behaviors in prevention of adolescent substance abuse. Adolescent Medicine: State of the Art Reviews. 1993;4(2):249-262.
Heather, N. Psychology and brief interventions. British Journal of Addiction. 1989;84:357-370.
Henggeler, S.W.; Melton, G.B.; Brondino, M.J.; Scherer, D.G.; and Hanley, J.H. Multisystemic treatment of juvenile offenders: Effects on adolescent behavior and family interaction. Developmental Psychology. 1986;22:132-141.
Henggeler, S.W.; Melton, G.B.; and Smith, L.A. Family preservation using multisystemic therapy: An effective alternative to incarcerating serious juvenile offenders. Journal of Consulting and Clinical Psychology. 1992;60:953-961.
Hoffman, N.G.; Mee-Lee, D.; and Arrowhead, A. Treatment issues in adolescent substance abuse and addictions: Options, outcomes, effectiveness, reimbursement and admission criteria. Adolescent Medicine: State of the Art Reviews. 1993;4:371-390.
Hoffmann, N.G.; Sonis, W.A.; and Halikas, J.A. Issues in the evaluation of chemical dependency treatment programs for adolescents. Pediatric Clinics of North America. 1987;34:449-459.
Hubbard, R.L.; Cavanaugh, E.R.; Craddock, S.G.; and Rachal, J.V. Characteristics, behaviors, and outcomes for youth in the TOPS. In: Friedman, A.S., and Beschner, G.M., eds. Treatment Services for Adolescent Substance Abusers. Treatment Research Monograph Series. DHHS Pub. No. (ADM) 85-1342. Rockville, MD: National Institute on Drug Abuse, 1985. pp. 49-65.
Hubbard, R.L.; Marsden, M.E.; Rachal, J.V.; Cavanaugh, E.R.; and Ginzburg, H.M. Drug Abuse Treatment: A National Study of Effectiveness. Chapel Hill, NC: University of North Carolina Press. 1989.
Inciardi, J.A.; Martin, S.S.; Butzin, C.A.; Hooper, R.M.; and Harrison, L.D. An effective model of prison-based treatment for drug-involved offenders. Journal of Drug Issues. 1997;27(2):261-278.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, DC: National Academy Press. 1990.
Jainchill, N. Therapeutic communities for adolescents: The same and not the same. In: De Leon, G., ed. Community as Method: Therapeutic Communities for Special Populations and Special Settings. Westport, CT: Praeger, 1997. pp. 161-177.
Jainchill, N.; Bhattacharya, G.; and Yagelka, J. Therapeutic communities for adolescents. In: Rahdert, E., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. NIDA Research Monograph Series, Number 156. Rockville, MD: National Institute on Drug Abuse, 1995. pp. 190-217.
Jainchill, N.; Yagelka, J.; Hawke, J.; and DeLeon, G. Adolescent admissions to residential drug treatment: HIV risk behaviors pre- and post-treatment. Journal of Psychoactive Drugs. in press.
Jainchill, N.; Yagelka, J.; Hawke, J.; and DeLeon, G. "Adolescent in Therapeutic Communities: One-Year Posttreatment Outcome." Manuscript in preparation.
Janus, M.D.; Burgess, A.W.; and McCormack, A. Histories of sexual abuse in adolescent male runaways. Adolescence. 1987a;22:405-417.
Janus, M.D.; McCormack, A.; Burgess, A.W.; and Hartman, C. Adolescent Runaways: Causes and Consequences. Lexington, MA: Lexington Books. 1987b.
Jessor, R. Risk behavior in adolescence: A psychosocial framework for understanding and action. Journal of Adolescent Health. 1991;12:597-605.
Jessor, R., and Jessor, S.L. Problem Behavior and Psychosocial Development: A Longitudinal Study of Youth. New York: Academic Press. 1977.
Johnson, V.E. I'll Quit Tomorrow. San Francisco: Harper and Row. 1980.
Johnston, L.; O'Malley, P.; and Bachman, J. National Survey Results on Drug Use From the Monitoring the Future Study 1975-1995. Rockville, MD: National Institute on Drug Abuse. 1995.
Kaminer, Y. Adolescent Substance Abuse: A Comprehensive Guide to Theory and Practice. New York: Plenum Press. 1994.
Keskinen, S. Hazelden Pioneer House, 1984 Profile: Six-Month and Twelve-Month Outcomes. Center City, MN: Hazelden. 1986.
Kipke, M.D.; O'Connor, S.; Palmer, R.; and MacKenzie, R.G. Street youth in Los Angeles: Profile of a group at high risk for human immunodeficiency virus infection. Archives of Pediatric and Adolescent Medicine. 1995;149(5):513-519.
Kipke, M.D.; Simon, T.R.; Montgomery, S.B.; Unger, J.B.; and Iversen, E.F. Homeless youth and their exposure to and involvement in violence while living on the streets. Adolescent Health. 1997;20(5):360-367.
Kipke, M.D.; Unger, J.B.; Palmer, R.F.; and Edgington, R. Drug use, needle sharing, and HIV risk among injection drug-using street youth. Substance Use and Misuse. 1996;31(9):1167-1187. [pmid: 8853236].
Klein, N.C.; Alexander, J.F.; and Parsons, B.V. Impact of family systems intervention on recidivism and sibling delinquency: A model of primary prevention and program evaluation. Journal of Consulting and Clinical Psychology. 1977;45(3):469-474. [pmid: 864062].
Kleinman, P.H.; Woody, G.E.; Todd, T.C.; Millman, R.B.; Kang, S.-Y.; Kemp, J.; and Lipton, D.S. Crack and cocaine abusers in outpatient psychotherapy. In: Onken, L.S., and Blaine, J.D., eds. Psychotherapy and Counseling in the Treatment of Drug Abuse. Washington, DC: U.S. Government Printing Office, 1990. pp. 24-35.
Knapp, J.; Templer, D.; Cannon, W.G.; and Dobson, S. Variables associated with success in an adolescent drug treatment program. Adolescence. 1991;26:305-317.
Knight, J.R. Adolescent substance use: Screening, assessment, and intervention in medical office practice. Contemporary Pediatrics. 1997;14(4):45-72.
Knight, J.R. Substance use, abuse, and dependency. In: Levine, M.D.; Carey W.B.; and Crocker, A.C., eds. Developmental-Behavioral Pediatrics, 3rd ed. Philadelphia: W.B. Saunders, in press.
Knight, K.; Simpson, D.; and Hiller, M.L. "Evaluation of prison-based treatment and aftercare: Process and outcomes." Presented at the Annual Meeting of the American Psychological Association, Toronto, Canada, August 1996.
Koopman, C.; Rosario, M.; and Rotheram-Borus, M.J. Alcohol and drug use and sexual behaviors placing runaways at risk for HIV infection. Addictive Behaviors. 1994;19:95-103.
Latimer, W.W.; Winters, K.C.; and Stinchfield, R.D. Screening for drug abuse among adolescents in clinical and correctional settings using the Problem-Oriented Screening Instrument for Teenagers. American Journal of Drug and Alcohol Abuse. 1997;23(1):79-98. [pmid: 9048149].
Laundergan, J.C. Easy does it: Alcoholism treatment outcomes, Hazelden and the Minnesota Model. Minneapolis: Hazelden Foundation. 1982.
Liddle, H.A. Family therapy techniques for adolescents with drug and alcohol problems. In: Snyder, W., and Ooms, T., eds. Empowering Families: ADAMHA Monograph from the First National Conference on the Treatment of Adolescent Drug, Alcohol, and Mental Health Problems. Washington, DC: U.S. Government Printing Office, 1992.
Liddle, H.A. The anatomy of emotions in family therapy with adolescents. Journal of Adolescent Research. 1994;9:120-157.
Liddle, H.A. Conceptual and clinical dimensions of a multidimensional, multisystems engagement strategy in family-based adolescent treatment. (Special issue. Adolescent Psychotherapy). Psychotherapy: Theory, Research, and Practice. 1995;32:39-58.
Liddle, H.A. Overview of family based treatments for adolescent problem behaviors. Journal of Family Psychology. 1996;10:3-11.
Liddle, H.A., and Dakof, G. Efficacy of family therapy for drug abuse: Promising but not definitive. Journal of Marital and Family Therapy. 1995a;21(4):511-543.
Liddle, H.A., and Dakof, G.A. Family-based treatment for adolescent drug abuse: State of the science. In: Rahdert, E., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. NIDA Research Monograph Series, Number 156. DHHS Pub. No. (ADM) 95-3908. Rockville, MD: National Institute on Drug Abuse, 1995b. pp. 218-254.
Liddle, H.A.; Dakof, G.; and Diamond, G. Adolescent substance abuse: Multi-dimensional family therapy in action. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse, 2nd ed. Boston: Allyn and Bacon, 1992. pp. 120-171.
MacKenzie, R.G. Influence of drug use on adolescent sexual activity. Adolescent Medicine: State of the Art Reviews 4(2):112-115, 1993.
McCormack, A.; Janus, M.D.; and Burgess, A.W. Runaway youths and sexual victimization: Gender differences in an adolescent runaway population. Child Abuse and Neglect. 1986;10:387-395.
McGoldrick, M.; Pearce, J.K.; and Giordano, J., eds. Ethnicity and Family Therapy. New York: Guilford Press. 1982.
McGue, M.; Pickens, R.W.; and Svikis, D.S. Sex and age effects on the inheritance of alcohol problems: A twin study. Journal of Abnormal Psychology. 1992;101:3-17.
Meyer, R.E. Psychopathology and Addictive Disorders. New York: Guilford Press. 1986.
Miller, W.R.; Benefield, R.G.; and Tonigan, J.S. Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting Psychology. 1993;61:455-461.
Miller, W.R., and Rollnick, S. Principles of motivational interviewing. Motivational Interviewing: Preparing People to Change Addictive Behavior. New York: Guilford Press, 1991.
Miller, W.R.; Zweben, A.; DiClemente, C.C.; and Rychtarik, R.G. Motivational Enhancement Therapy Manual: A Clinical Research Guide for Therapists Treating Individuals With Alcohol Abuse and Dependence. Project MATCH, Monograph Series, Volume 2. DHHS Pub. No. (ADM) 92-1894. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism. 1992.
Myers, T.; Rowe, C.J.; Tudiver, F.G.; Kurtz, R.G.; Jackson, E.A.; Orr, K.W.; and Bullock, S.L. HIV, substance use and related behaviour of gay and bisexual men: An examination of the talking sex project cohort. British Journal of Addiction. 1992;87(2):207-214. [pmid: 1554997].
National Institute of Justice. Drug Use Forecasting: 1993 Annual Report on Juvenile Arrestees/Detainees: Research in Brief. Washington, DC: National Institute of Justice. 1994.
National Institute of Justice. Drug Use Forecasting: 1996 Annual Report on Adult and Juvenile Arrestees. Washington, DC: National Institute of Justice. 1997.
National Institute on Drug Abuse. Monitoring the Future Study. Rockville, MD: National Institute on Drug Abuse. 1996a.
National Institute on Drug Abuse. National Pregnancy and Health Survey: Drug Use Among Women Delivering Live Births 1992. Rockville, MD: National Institute on Drug Abuse. Division of Epidemiology and Prevention Research. 1996b.
National Institute on Drug Abuse. National Survey Results on Drug Use From the Monitoring the Future Study 1975-1995: Volume II, College Students and Young Adults (1997). Rockville, MD: National Institute on Drug Abuse. Division of Epidemiology and Prevention Research. 1998.
Newcomb, M.D., and Bentler, P.M. Substance use and abuse among children and teenagers. American Psychologist. 1989;44(2):42B248.
Nichols, M., and Schwartz, R. Family Therapy. 4th ed. Needham Heights, MA: Allyn and Bacon Publishers. 1998.
Oetting, E.R., and Beavais, F. Peer cluster theory: Drugs and the adolescent. Journal of Counseling and Development. 1986;65:17-27.
Patterson, G.R. Coercive Family Process. Eugene, OR: Castalia Publishing. 1982.
Pompi, K.F. Adolescents in therapeutic communities: Retention and posttreatment outcome. In: Tims, F.; DeLeon, G.; and Jainchill, N., eds. Therapeutic Community: Advances in Research and Application. NIDA Research Monograph Series, Number 144. DHHS Pub. No. (ADM) 94-3633. Rockville, MD: National Institute on Drug Abuse, 1994.
Prochaska, J.O., and DiClemente, C.C. Levels of change in the modification of problem behavior. In: Hersen, M.; Eisler, R.; and Miller, P.M., eds. Progress in Behavior Modification. Vol. 28. Sycamore, IL: Sycamore Publishing, 1982.
Prochaska, J.O., and DiClemente, C.C. Transtheoretical therapy: Toward a more integrative model of change. Psychotherapy: Theory, Research and Practice. 1982;19:276-278.
Remafedi, G.; Farrow, J.A.; and Deisher, R.W. Risk factors for attempted suicide in gay and bisexual youth. Pediatrics. 1991;81:869-875.
Resnick, M.D.; Bearman, P.S.; Blum, R.W.; Bauman, K.E.; Harris, K.M.; Jones, J.; Tabor, J.; Beuhring, T.; Sieving, R.E.; Shew, M.; Ireland, M.; Bearinger, L.H.; and Udry, J.R. Protecting adolescents from harm. Findings from the National Longitudinal Study on Adolescent Health. Journal of the American Medical Association. 1997;278(10):823-832. [pmid: 9293990].
Richter, S.; Brown, S.; and Mott, M. The impact of social support and self-esteem on adolescent substance abuse treatment outcome. Journal of Substance Abuse. 1991;3:371-385.
Rockholz, P.B. "Follow-up study of clients from an adolescent therapeutic community." Columbia University, unpublished manuscript, 1978.
Rockholz, P.B. "Treatment of adolescents with alcohol, drug abuse and mental health problems." Presentation at conference sponsored by the Alcohol, Drug Abuse, and Mental Health Administration, Alexandria, VA, October 2-4, 1989.
Rockholz, P.B.; McMahon, T.J.; and Luthar, S. Improving residential substance abuse treatment for inner-city teens: New Haven ACTS. In: Crowley, T.J., and Beal, J. M., Chairs. Adolescents and Substance Abuse. Symposium conducted at the annual scientific meeting of the College on Problems of Drug Dependence, San Juan, Puerto Rico, 1996.
Rollnick, S., and Bell, A. Brief motivational interviewing for use by the nonspecialist. In: Miller, W., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press, 1991. pp. 203-213.
Rollnick, S.; Heather, N.; and Bell, A. Negotiating behavior change in medical settings: The development of brief motivational interviewing. Journal of Mental Health. 1992;1:25-37.
Rosenthal, M.S., and Biase, D.V. Phoenix houses: Therapeutic communities for drug addicts. In: Kaplan, H.I., and Sadock, B.J., eds. Modern Group Book III: Groups and Drugs. New York: E. P. Dutton and Company, 1971.
Rouse, B.A., ed. Substance Abuse and Mental Health Statistics Sourcebook. DHHS Pub. No. (SMA) 95-3064. Rockville, MD: Substance Abuse and Mental Health Services Administration. 1995.
Rush, T.V. Predicting treatment outcomes for juvenile and young adult clients in Pennsylvania substance-abuse system. In: Beschner, G.M., and Friedman, A.S., eds. Youth Drug Abuse. Lexington, MA: Lexington Books, 1979. pp. 629-656.
Schmidt, S.; Liddle, H.A.; and Dakof, G.A. Multidimensional family therapy: Parenting practices and symptom reduction in adolescent drug abuse. Journal of Family Psychology. 1996;10:12-27.
Schuckit, M.A. Biological vulnerability to alcoholism. Journal of Consulting and Clinical Psychology. 1987;55:301-309.
Sells, S.B., and Simpson, D.D. Evaluation of treatment outcome for youths in the Drug Abuse Reporting Program (DARP): A follow-up study. In: Beschner, G.M., and Friedman, A.S., eds. Youth Drug Abuse: Problems, Issues, and Treatment. Lexington, MA: D.C. Heath, 1979.
Shedler, J., and Block, J. Adolescent drug use and psychological health. American Psychologist. 1990;5:612-630.
Sibthorpe, B.; Drinkwater, J.; Gardner, K.; and Bammer, G. Drug use, binge drinking and attempted suicide among homeless and potentially homeless youth. Australian and New Zealand Journal of Psychiatry. 1995;29(2):248-256. [pmid: 7487787].
Stanton, M.D., and Shadish, W.R. Outcome, attrition, and family-couples treatment for drug abuse: A meta-analysis and review of the controlled, comparative studies. Psychological Bulletin. 1997;122(2):170-191. [pmid: 9283299].
Stanton, M.D., and Todd, T.C. Structural family therapy with drug addicts. In: Kaufman, E., and Kaufmann, P., eds. The Family Therapy of Drug and Alcohol Abuse. New York: Gardner Press, 1979.
Stanton, M.D., and Todd, T.C., eds. The Family Therapy of Drug Abuse and Addiction. New York: Guilford Press. 1982.
Stiffman, A.R. Physical and sexual abuse in runaway youths. Child Abuse and Neglect. 1989;13:417-426.
Stinchfield, R.D.; Owen, P.L.; and Winters, K.C. Group therapy for substance abuse: A review of the empirical literature. In: Fuhriman, A., and Burlinggame, G.M., eds. Handbook of Group Psychotherapy: An Empirical and Clinical Synthesis. New York: John Wiley and Sons, 1994. p. 459.
Stuckey, R.F., and Harrison, J.S. The alcoholism rehabilitation center. In: Pattison, E.M., and Kaufman, E., eds. Encyclopedic Handbook of Alcoholism. New York: Gardner Press, 1982.
Substance Abuse and Mental Health Services Administration. National Household Survey on Drug Abuse: Population Estimates 1995. Rockville, MD: SAMHSA, Office of Applied Studies. 1996.
Substance Abuse and Mental Health Services Administration. National Household Survey on Drug Abuse: Population Estimates 1997. Rockville, MD: SAMHSA, Office of Applied Studies. 1998a.
Substance Abuse and Mental Health Services Administration. Services Research Outcomes Study: September 1998. Rockville, MD: SAMHSA, Office of Applied Studies. 1998b. [Accessed September 15, 1998.].
Szapocznik, J.; Kurtines, W.M.; Foote, F.H.; Perez-Vidal, A.; and Hervis, O. Conjoint versus one-person family therapy: Further evidence for the effectiveness of conducting family therapy through one person. Journal of Consulting and Clinical Psychology. 1983;51:889-899.
Szapocznik, J.; Kurtines, W.M.; Santisteban, D.A.; and Rio, A.T. Interplay of advances between theory, research, and applications in treatment interventions aimed at behavior problem children and adolescents. Journal of Consulting and Clinical Psychology. 1990;58:696-703.
Szapocznik, J.; Perez-Vidal, A.; Brickman, A.L.; Foote, F.H.; Santisteban, D.A.; Hervis, O.; and Kurtines, W.M. Engaging adolescent drug abusers and their families in treatment: A strategic structural systems approach. Journal of Consulting and Clinical Psychology. 1988;56(4):552-557. [pmid: 3198813].
Thompson, T.; Koermer, J.; and Grabowski, J. Brokerage model rehabilitation system for opiate dependence: A behavioral analysis. In: Grabowski, J.; Stitzer, M.; and Henningfield, J., eds. Behavioral Interventions in Drug Abuse Treatment. NIDA Research Monograph Series, Number 46. DHHS Pub. No. (ADM) 84-1282. Rockville, MD: National Institute on Drug Abuse, 1984. pp. 131-146.
Warren, J.K.; Gary F.; and Moorhead, J. Self-reported experiences of physical and sexual abuse among runaway youths. Perspectives in Psychiatric Care. 1994;30:23-28.
Weiss, G., and Hechtman, L.T. Hyperactive Children Grown Up: AD/HD in Children, Adolescents, and Adults. 2nd ed. New York: Guilford Press. 1993.
Wexler, H.K.; DeLeon, G.; Thomas, G.; Kressel, D.; and Peters, J. The Amity prison TC evaluation: Reincarceration outcomes. Journal of Criminal and Justice Behavior. in press.
Widom, C.S. Childhood victimization and adolescent problem behaviors. In: Ketterlinus, R.D., and Lamb, M.E., eds. Adolescent Problem Behaviors: Issues and Research. Hillsdale, NJ: Lawrence Erlbaum, 1994. pp. 127-164.
Wilens, T.E.; Biederman, J.; Spencer, T.J.; and Frances, R.J. Comorbidity of attention-deficit hyperactivity and psychoactive substance use disorders. Hospital and Community Psychiatry. 1994;45:421-435.
Windle, M. Substance use and abuse among adolescent runaways: A four-year follow-up study. Journal of Youth and Adolescence. 1989;18:331-344.
Windle, M., and Windle, R. The continuity of behavioral expression among disinhibited and inhibited childhood subtypes. Clinical Psychology Review. 1993;13:741-761.
Winters, K.C.; Latimer, W.W.; and Stinchfield, R. The role of psychosocial factors as determinants of drug abuse among treatment youths. Journal of Child and Adolescent Substance Abuse. in press.
Winters, K.C., and Schiks, M. Assessment and treatment of adolescent chemical dependency. In: Keller, P., ed. Innovations in Clinical Practice: A Source Book. Vol. 8. Sarasota, FL: Professional Resource Exchange, 1989. pp. 213-228.
Winters, K.C.; Stinchfield, R.; Opland, E.O.; Weller, C.; and Latimer, W.W. Characterizing the effectiveness of the Minnesota Model approach in the treatment of adolescent drug abusers. Submitted for publication, 1998.