# Consensus Panel

1997-98 Revision Consensus Panel Chair
- Ken Winters, Ph.D.
- Associate Professor
- Department of Psychiatry
- University of Minnesota Hospital and Clinic
- Minneapolis, Minnesota

1997-98 Revision Consensus Panel
- Gayle A. Dakof, Ph.D.
- Research Assistant Professor
- Center for Family Studies
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- Miami, Florida
- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida
- Nancy Jainchill, Ph.D.
- Senior Principal Investigator
- Center for Therapeutic Community Research
- National Development and Research Institutes
- New York, New York
- Michele D. Kipke, Ph.D.
- Director
- Board on Children, Youth, and Families National Research Council
- Institute of Medicine
- Washington, D.C.
- John R. Knight, M.D.
- Associate Director for Medical Education
- Division on Addictions
- Harvard Medical School
- Assistant in Medicine
- Children's Hospital
- Boston, Massachusetts
- Howard Liddle, Ed.D.
- Professor and Director
- Center for Treatment Research and Adolescent Drug Abuse
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- Miami, Florida

1992--93 Consensus Panel Co-Chairs
- Tom McLellan, Ph.D.
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania
- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

1992--93 Workgroup Leaders
- Murray Durst
- Manager
- Substance Abuse Programs
- National Council for Juvenile and Family Court Judges
- University of Nevada
- Reno, Nevada
- Terence McSherry, M.P.H., M.P.A.
- Executive Director
- North-East Treatment Centers
- Philadelphia, Pennsylvania
- Roger Peters, Ph.D.
- University of South Florida
- Florida Mental Health Institute
- Department of Law and Mental Health
- Tampa, Florida

1992--93 Workgroup Members
- Linda Albrecht
- Facility Director
- Lansing Residential Center
- New York State Division for Youth
- Lansing, New York
- Jack Araza, Ph.D.
- Nevada Certified Psychologist and Alcohol and Drug Abuse Counselor
- Carson City, Nevada
- Andrea G. Barthwell, M.D.
- Medical Director
- Interventions
- Chicago, Illinois
- La Claire Bouknight, M.D., F.A.C.P.
- Medical Director
- Residential Care Division
- Michigan Department of Social Services
- Maxey Training School
- Whitmore Lake, Michigan
- Wesley R. Bowman, Ph.D.
- Licensed Psychologist
- Director
- PACE, Inc.
- Wilmington, Delaware
- Margaret K. Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Cheryl G. Davis, M.S.W.
- Mental Health and Substance Abuse Advisor
- Chelsea School District
- Chelsea, Michigan
- Donald W. Dew, Ed.D., C.R.C.
- Director of Regional Rehabilitation and Continuing Education Program
- Washington, D.C.
- Harvey M. Goldstein
- Assistant Director for Probation
- Administration Office of the Courts
- Trenton, New Jersey
- Peter E. Leone, Ph.D.
- Associate Professor
- University of Maryland
- Department of Special Education
- College Park, Maryland
- Kenneth F. Pompi, Ph.D.
- Vice President
- Research and Information Management
- Abraxas Group, Inc.
- Pittsburgh, Pennsylvania
- Gloria M. Roney, L.I.S.W.
- Clinical Director
- Hogares Incorporated
- Albuquerque, New Mexico
- John L. Syphax, M.D.
- Director
- Inpatient Psychiatry
- Howard University Hospital
- Washington, D.C.
- Anne Wake, Ph.D.
- Private Practitioner
- Washington, D.C.
- Barbara J. Wiest, M.A.
- Program Supervisor
- Youth Alcohol and Drug Treatment and Prevention Programs
- Clackamas County Mental Health
- Marylhurst College
- Marylhurst, Oregon