# Appendix D—Field Reviewers

- Jack Araza, Ph.D., C.A.D.C.
- Carson City, Nevada

- Robert Bick, M.A., S.A.C.
- Director
- Champlain Drug and Alcohol Services
- Howard Center for Human Services
- South Burlington, Vermont

- Ted Blevins
- Executive Director
- Lena Pople Home, Inc.
- Fort Worth, Texas

- Saroja A. Boaz
- Executive Director
- Intake Assessment and Referral Center
- Flint, Michigan

- Patricia Bradford, L.I.S.W., L.M.F.T., C.T.S.
- P.A. Bradford and Associates
- Columbia, South Carolina

- Patricia Cummings, M.S.S.W., L.C.S.W.
- Prevention Director/Planning Officer
- Seven Counties Services, Inc.
- Louisville, Kentucky

- John de Miranda, Ed.M.
- Executive Director
- National Association on Alcohol, Drugs, and Disability, Inc.
- San Mateo, California

- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

- Jean Anne Donaldson, M.A.
- Public Health Advisor
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Pamela L. Donaldson, A.R.N.P.-C., C.A.R.N., Ph.D.
- Post-Doctoral Fellow
- Columbia University
- New York State Psychiatric Institute

- Lynn Dorman, Ph.D., J.D.
- Brattleboro, Vermont

- David Duncan, Dr.P.H., C.A.S.
- Associate Professor
- Center for Alcohol and Addiction Studies
- Brown University
- Providence, Rhode Island

- Bryan R. Ellis, M.A., C.S.W.
- President
- ADE Incorporated
- Clarkston, Michigan

- Janice Embree-Bever, M.A., C.A.C. III
- Planning/Grants Officer III
- Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado

- Jerry P. Flanzer, D.S.W.
- Director
- Recovery and Family Treatment, Inc.
- Alexandria, Virginia

- Luis E. Flores, M.A.
- Associate Administrator
- Stop Child Abuse and Neglect, Inc.
- Laredo, Texas

- Lawrence S. Friedman, M.D.
- Chief
- Division of Primary Care Pediatrics and Adolescent Medicine
- University of California at San Diego
- San Diego, California

- Anthony B. Gerard, Ph.D.
- Senior Project Director
- Western Psychological Services
- Los Angeles, California

- Michael F. Goodnow
- Social Science Program Specialist
- Training and Technical Assistance Division
- Office of Juvenile Justice and Delinquency Prevention
- Department of Justice
- Washington, D.C.

- Larry Halverson, M.D.
- Springfield, Missouri

- James Herrera, M.A., L.P.C.C.
- Center on Alcoholism, Substance Abuse and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- Richard Heyman, M.D.
- Chair, Committee on Substance Abuse
- American Academy of Pediatrics
- Cincinnati, Ohio

- Norman G. Hoffmann, Ph.D.
- Director, Policy Program
- Center for Alcohol and Addiction Studies
- Department of Community Health
- Brown University
- Providence, Rhode Island

- Edward L. Huggins, M.Div.
- Clinical Supervisor
- Offsite Services
- Alcohol and Drug Youth Services
- Fairfax--Falls Church Community Services Board
- Falls Church, Virginia

- John Rogers Knight, M.D.
- Associate Director for Medical Education
- Division on Addictions
- Harvard Medical School
- Assistant in Medicine
- Children's Hospital
- Boston, Massachusetts

- Joan Kub, Ph.D., R.N.
- Assistant Professor
- School of Nursing
- Johns Hopkins University
- Baltimore, Maryland

- Victor Lidz, Ph.D.
- Assistant Professor
- Institute for Addictive Disorders
- Allegheny University of Health Science
- Philadelphia, Pennsylvania

- James McDermott, C.A.C., N.C.A.C. II, C.A.S., C.H.E.S.
- Project Coordinator
- Bureau of Counseling
- New York State Office of Children and Families Service
- Rensselaer, New York

- Colleen R. McLaughlin, Ph.D.
- Senior Research Analyst
- Department of Surgery
- Medical College of Virginia
- Richmond, Virginia

- Thomas J. McMahon, Ph.D.
- Assistant Professor of Psychology
- Yale School of Medicine
- Substance Abuse Center
- New Haven, Connecticut

- Terence McSherry, M.S.P.H., M.S.P.A.
- President and CEO
- Northeast Treatment Centers Inc.
- Philadelphia, Pennsylvania

- E. Carolina Montoya, Psy.D.
- Director
- Miami Dade County
- Office of Rehabilitative Services
- Department of Human Services
- Miami, Florida

- Andrew Morral
- RAND
- Santa Monica, California

- David F. O'Connell, Ph.D.
- Corporate Clinical Director
- Adolescent Treatment Services
- Caron Foundation
- Wernersville, Pennsylvania

- Roger H. Peters, Ph.D.
- Associate Professor
- Department of Mental Health Law and Policy
- Louis de la Parte Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Elizabeth Rahdert, Ph.D.
- Research Psychologist
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Scott M. Reiner, M.S., C.A.C., C.C.S.
- Substance Abuse Program Supervisor
- Substance Abuse Services Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- Steve Riedel, M.S.Ed.
- Associate Director
- Our Home, Inc.
- 360 Ohio, Southwest
- Huron, South Dakota

- D. Paul Robinson, M.D.
- Division of Adolescent Medicine
- Children's Hospital of Missouri
- One Hospital Drive
- Columbia, Missouri

- Peter B. Rockholz, M.S.S.W.
- Director
- Residential Services
- APT Foundation, Inc.
- Newtown, Connecticut

- Sarah E. Shapleigh, M.S.W., C.A.D.C.
- Counselor
- Chemical Dependency Services Department
- Grasmere Intermediate Care Facility, Mentally Ill
- Chicago, Illinois

- Lawrence M. Sideman, Ph.D.
- Clinical Director/Assistant Director
- Treatment Assessment Screening Center, Inc.
- Phoenix, Arizona

- Anne H. Skinstad, Psy.D.
- Division of Counseling, Rehabilitation and Student Development
- Iowa Addiction Technology Training Center
- University of Iowa
- Iowa City, Iowa

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- James C. Taylor, M.A., C.A.D.C. II
- Alcohol and Drug Treatment Coordinator
- Hillcrest Youth Correctional Facility
- Salem, Oregon

- Sally Towns, M.Ed., M.S.W.
- Mental Health Specialist
- Louisiana Office of Mental Health
- Baton Rouge, Louisiana

- William L. White, M.S.
- Senior Research Consultant
- Lighthouse Institute
- Chestnut Health Systems, Inc.
- Bloomington, Illinois