# Appendix A--Bibliography

Achenbach, T.M. Manual for the Youth Self-Report and 1991 Profile. Burlington, VT: University of Vermont Department of Psychiatry. 1991.
Achenbach, T.M., and Edelbrock, C.S. Behavioral problems and competencies reported by parents of normal and disturbed children aged 4-16. Monographs of the Society for Research in Child Development 46(1, Serial No. 88). 1981.
American Academy of Pediatrics. The Classification of Child and Adolescent Mental Diagnoses in Primary Care: Diagnostic and Statistical Manual for Primary Care (DSM-PC) Child and Adolescent Version. Elk Grove Village, IL: American Academy of Pediatrics. 1996.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. (DSM-IV). Washington, DC: American Psychiatric Association. 1994.
Baumrind, D., and Moselle, K.A. A developmental perspective on adolescent drug abuse. Advances in Alcohol and Substance Abuse. 1985;4:41-67.
Beck, A.T., and Ward, J. Beck Depression Inventory (BDI). In: Depression: Causes and Treatment. Philadelphia, PA: University of Pennsylvania Press. 1972.
Benishek, L.A. A Summary of Adolescent Substance Abuse Assessment Instruments. East Lansing, MI: Michigan State University. 1989.
Boleloucky, Z., and Horvath, M. SCL-90 rating scale: First experience with the Czech version in healthy male scientific workers. Archives of Nervous Disorders. 1974;16(2):115-116.
Botvin, G.J.; Baker, E.; Dusenbury, L.; Tortu, S.; and Botvin, E.M. Preventing adolescent drug abuse through a multimodal cognitive-behavioral approach: Results of a 3-year study. Journal of Consulting and Clinical Psychology. 1990;58(4):437-446. [pmid: 2212181].
Botvin, G.J.; Epstein, J.A.; Baker, E.; Diaz, T.; and Williams, I.W. School based drug abuse prevention with inner city minority youth. Journal of Child and Adolescent Substance Abuse. 1997;6(1):5-19.
Brayfield, A.H., and Rothe, H.F. An index of job satisfaction. Journal of Applied Psychology. 1951;35:307-311.
Brinson, J.A. Group work for adolescent substance users: Some issues and recommendations. Journal of Child and Adolescent Substance Abuse. 1995;4(2):49-60.
Brodman, K.; Erdman, A.; Lorge, I.; and Wolff, H. The Cornell Medical Index: An adjunct to medical interview. Journal of the American Medical Association. 1949;140:530-534.
Carroll, K.M.; Rounsaville, M.D.; and Gawin, F.H. A comparative trial of psychotherapies for ambulatory cocaine abusers: Relapse prevention and interpersonal psychotherapy. American Journal on Drug and Alcohol Abuse. 1991;17(3):229-247.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Disease. Treatment Improvement Protocol (TIP) Series, Number 11. DHHS Publication No. (SMA) 24-2094. Washington, DC: U.S. Government Printing Office. 1994.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 14. DHHS Pub. No. (SMA) 95-3031. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series, Number 21. DHHS Pub. No. (SMA) 95-3051. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, Number 23. DHHS Publication No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office. 1996.
Center for Substance Abuse Treatment. Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 31. DHHS Pub. No. (SMA) 99-3283. Washington, DC: U.S. Government Printing Office. 1999.
Centers for Disease Control and Prevention. http://www.cdc.gov/nccdphp/dash/yrbs/ov.htm [Accessed April 6, 1998].
Children's Defense Fund. The Adolescent and Young Adult Fact Book. Washington, DC: Children's Defense Fund. 1991.
Conoley, J.C., and Impara, J.C., eds. The Twelfth Mental Measurements Yearbook. Lincoln, NE: The Buros Institute of Mental Measurements. 1995.
Conoley, J.C., and Kramer, J.J., eds. The Tenth Mental Measurements Yearbook. Lincoln, NE: The Buros Institute of Mental Measurements. 1989.
Cook, F. TASC:. Case management models linking criminal justice and treatment. In: Ashery, R.S., ed. Progress and Issues in Case Management. NIDA Research Monograph Series, Number 127. DHHS Pub. No. (ADM) 92-1946. Rockville, MD: National Institute on Drug Abuse. 1992.
Costello, A.; Edelbrock, C.; Dulcan, M.; Kalas, R.; and Klaric, S. "Final Report to NIMH on the Diagnostic Interview Schedule for Children." Unpublished manuscript. 1984.
Davis, A.R., and Ware, J.E. Measuring Health Insurance Experiment (R-2711-HHS). Santa Monica, CA: Rand Corporation. 1984.
Davis, N.; Moss, H.; Kirisci, L.; and Tarter, R. Neighborhood crime rates among drug abusing and nondrug abusing families. Journal of Child and Adolescent Substance Abuse. 1996;5(4):1-14.
Dembo, R., and Associates. Prototype Screening/Triage Form for Juvenile Detention Centers. Tampa, FL: Department of Criminology, University of South Florida. 1990.
Dembo, R., and Shern, D. Relative deviance and the process(es) of drug involvement among inner city youths. The International Journal of the Addictions. 1982;17(8):1973-1999.
Dembo, R.; Williams, L.; Fagan, J.; and Schmeidler, J. The relationships of substance abuse and other delinquency over time in a sample of juvenile detainees. Criminal Behavior and Mental Health. 1993;3:158-179.
Dembo, R.; Williams, L.; and Schmeidler, J. Addressing the problems of substance abuse in juvenile corrections. In: Inciardi, J.A., ed. Drug Treatment in Criminal Justice Settings. Newbury Park, CA: Sage. 1993.
Dembo, R.; Williams, L.; Wish, E.D.; Berry, E.; Getreu, A.; Washburn, M.; and Schmeidler, J. Examination of the relationships among drug use, emotional/psychological problems, and crime among youths entering a juvenile detention center. International Journal of the Addictions. 1990;25(11):1301-1340. [pmid: 2090629].
Dembo, R.; Williams, L.; Wish, E.D., Schmeidler, J. Urine Testing of Detained Juveniles to Identify High-Risk Youth. Washington, DC: U.S. Department of Justice. 1990.
Derogatis, L.R. SCL-90 Administration, Scoring and Procedures Manual. Baltimore, MD: Johns Hopkins University School of Medicine. 1977.
Derogatis, L.R., and Melisaratos, N. The Brief Symptom Inventory: An introductory report. Psychological Medicine. 1983;13:595-605.
Derogatis, L.R., and Cleary, P. Confirmation of the dimensional structure of the SCL-90: A study in construct validation. Journal of Clinical Psychology. 1977;33(4):981-989.
Derogatis, L.R., and Cleary, P. Factorial invariance across gender for the primary symptom dimensions of the SCL-90. British Journal of Social Clinical Psychology. 1977;16:347-356.
Derogatis, L.R.; Rickels, K.; and Rock, A. The SCL-90 and the MMPI: A step in the validation of a new self-report scale. British Journal of Social Clinical Psychology. 1976;128:280-289.
Dubrow, N., and Garbarino, J. Living in the war zone: Mothers and young children in a public housing development. Child Welfare. 1989;58:3-20.
Duncan, D.F. Problems associated with three commonly used drugs: A survey of secondary school students. Psychology of Addictive Behavior. 1992;5(2):1-5.
Duncan, D.F. Growing up under the gun: Children and adolescents coping with violent neighborhoods. Journal of Primary Prevention. 1996;16(4):343-356.
Edwards, D.W.; Yarvis, R.M.; Mueller, D.P.; Zingale, H.C.; and Wagman, W.J. Test-taking and the stability of adjustment scales. Evaluation Quarterly. 1978;2(2):275-291.
Elliott, D.S.; Huizinga, D.; and Ageton, S.S. Explaining Delinquency and Drug Use. Beverly Hills, CA: Sage Publications. 1985.
Epstein, J.L., and McPartland, J.M. In: Epstein, J.L., and McPartland, J.M., eds. Manual for the Quality of School Life Scale. Boston: Houghton Mifflin. 1978.
Eysenck, H.J. The Maudsley Personality Inventory. London: University of London Press. 1959.
Farrow, J.A.; Smith, W.R.; and Hurst, M.D. Adolescent drug and alcohol assessment instruments in current use: A critical comparison. Seattle, WA: Department of Pediatrics, University of Washington. 1993.
Fournier, D.G.; Olson, D.H.; and Druckman, J.M. Assessing marital and premarital relationships: The PREPARE-ENRICH Inventories. In: Filsinger, E.E., ed., Marital and Family Assessment. Beverly Hills, CA: Sage Publications. 1983.
Fowers, B.J., and Olson, D.H. Predicting marital success with PREPARE: A predictive validity study. Journal of Marriage and Family Therapy. 1986;12:403-413.
Friedman, C.J., and Friedman, A.S. Drugs and delinquency. Drug Use in America: Problem in Perspective 1:398-487. The technical papers on the Second Report of National Commission on Marijuana and Drug Abuse, Washington, DC: U.S. Government Printing Office. 1973.
Furberg, C.D., and Elinson, J. In: Furberg, C.D. and Elinson, J., eds. Assessment of Quality of Life in Clinical Trials of Cardiovascular Disease. NY: Le Jacq Publishing. 1984.
Gavin, D.R.; Ross, H.E.; and Skinner, H.A. Diagnostic validity of the drug abuse screening test in the assessment of DSM-III drug disorders. British Journal of Addiction. 1989;84:301-307.
Gawin, F.H., and Kleber, H.D. Cocaine abuse treatment. Archives of General Psychiatry. 1984;44:903-909.
Glantz, M., and Pickens, R. Vulnerability to Drug Abuse. Washington, DC: American Psychological Association. 1992.
Goffman, T.J. The Presentation of Self in Everyday Life. Garden City, NY: Doubleday. 1959.
Gunderson, E.K.; Russell, J.W.; and Nail, R.L. A drug involvement scale for classification of drug abusers. Journal of Community Psychology. 1973;1:399-403.
Hagborg, W.J. The Revised Problem Behavior Checklist and severely emotionally disturbed adolescents: Relationship to intelligence, academic achievement, and sociometric ratings. Journal of Abnormal Child Psychology. 1990;18:47-53.
Harrell, T.H.; Honaker, L.M.; and Davis, E. Cognitive and behavioral dimensions of dysfunction in alcohol and polydrug abusers. Journal of Substance Abuse. 1991;3:415-426.
Hater, J.J., and Simpson, D.D. "The PMES Information Form on Family, Friends, and Self: A Report on Scale Construction." Report to Drug Abuse Prevention Division (DAPD), and the Texas Department of Community Affairs (TDCA). 1981.
Havighurst, R. J. Developmental Tasks and Education, 3rd ed. New York: David McKay. 1972.
Hedlund, J.L., and Vieweg, M.S. The Michigan Alcoholism Screening Test (MAST): A comprehensive review. The Journal of Operational Psychiatry. 1984;15:55-65.
Henly, G.A., and Winters, K.C. Development of problem severity scales for the assessment of adolescent alcohol and drug abuse. The International Journal of the Addictions. 1988;23:65-85.
Henly, G.A., and Winters, K.C. Development of psychosocial scales for the assessment of adolescent alcohol and drug involvement. The International Journal of the Addictions. 1989;24:973-1001.
Hubbard, R. The Washington, D.C. Diagnostic, Referral, Data, and Data Management Unit. Research Triangle Park, NC: Research Triangle Institute. 1991.
Impara, J.C., and Plake, B.S., eds. The Thirteenth Mental Measurements Yearbook. Lincoln, NE: The Buros Institute of Mental Measurements. 1998.
Inwald, R.E.; Brobst, M.A.; and Morissey, R.F. Identifying and predicting adolescent behavioral problems by using a new profile. Juvenile Justice Digest. 1986;14(3).
Ivens, C., and Rehm, L.P. Assessment of childhood depression: Correspondence between reports by child, mother, and father. Journal of the American Academy of Child and Adolescent Psychiatry. 1988;6:738-741.
Jacob, T., and Tennenbaum, D. Family Assessment Methods. In: Rutter, M.; Tuma, H.; and Lann, I., eds. Assessment and Diagnosis of Child and Adolescent Psychopathology. NY: Guilford Press. 1987.
Jainchill, N.; Yagelka, J.; and DeLeon, G. Adolescent admissions to residential drug treatment: HIV risk behaviors pre-and post-treatment. Psychology of Addictive Behaviors, in press.
Jastak, S.F., and Wilkinson, G.S. Wide Range Achievement TestCLevel I and II, rev. ed. Wilmington, DE: Jastak Associates. 1984.
Jenkins, W.O.; Witherspoon, A.D.; DeVine, M.D.; deValera, E.R.; Muller, J.B.; Barton, M.C.; and McKee, J.M. The Post-Prison Analysis of Criminal Behavior and Longitudinal Followup Evaluation of Institutional Treatment. Rehabilitation Research Foundation, #RRF-910-2-74, Manpower Administration. Tuscaloosa, AL: Behavior Science Press. 1974.
Jessor, R., and Jessor, S. Problem Behavior and Psychosocial Development: A Longitudinal Study of Youth. NY: Academic Press. 1977.
Kramer, J.J., and Conoley, J.C., eds. The Eleventh Mental Measurements Yearbook. Lincoln, NE: The Buros Institute of Mental Measurements. 1992.
Krug, S.E., and Laughlin, J.E. IPAT Depression Scale. Savoy, IL: Institute for Personality and Ability Testing. 1976.
Labouvie, E. Alcohol and marijuana use in adolescent stress. International Journal of the Addictions. 1986;21(3):333-345. [pmid: 3721639].
Leccese, M., and Waldron, H.B. Assessing adolescent substance abuse: A critique of current measurement instruments. Journal of Substance Abuse Treatment. 1994;11:553-563.
Leigh, B.C., and Stall, R. Substance use and risky sexual behavior for exposure to HIV. Issues in methodology, interpretation, and prevention. American Psychologist. 1993;48(10):1035-1045. [pmid: 8256876].
Liddle, H.A., and Dakof, G.A. Family-based treatment for adolescent drug use: State of the science. In: Rahdert, E., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. Rockville, MD: National Institute on Drug Abuse. 1995.
Manson, M.P., and Huba, G.J. The Manson Evaluation Manual. Los Angeles: Western Psychological Services. 1987.
Martin, C.S.; Kaczynski, N.A.; Maisto, S.A.; Bukstein, O.M.; and Moss, H.B. Patterns of DSM-IV alcohol abuse and dependence symptoms in adolescent drinkers. Journal of Studies on Alcohol. 1995;56:672-680.
McCubbin, H.; Larson, A.; and Olsen, D.H. (1982). (F-Copes) Family coping strategies. In: Olsen, D.H.; McCubbin, H.I.; Barnes, H.; Larson, A.; Muxen, M.; and Wilson, M., eds. Family Inventories: Inventories Used in a National Survey of Families Across the Family Life Cycle. St. Paul, MN: Family Social Science, University of Minnesota. 1989.
McLellan, A.T.; Luborsky, L.; Woody, G.E.; and O'Brien, C.P. An improved diagnostic evaluation instrument for substance abuse clients: The Addiction Severity Index. The Journal of Nervous and Mental Disease. 1980;168(1):26-33. [pmid: 7351540].
Moore, R.A. The diagnosis of alcoholism in a psychiatric hospital: A trial of the Michigan Alcohol Screening Test (MAST). American Journal of Psychiatry. 1972;128(12):115-119.
Moos, R.H. Combined Preliminary Manual for the Family, Work, and Group Environment Scales. Palo Alto, CA: Consulting Psychologists Press. 1974.
Moos, R.H. Conceptual and empirical approaches to developing family-based assessment procedures: Resolving the case of the family environment scale. Family Process. 1990;29:199-208.
Moos, R.H., and Moos, B.S. Family Environment Scale: Manual. Palo Alto, CA: Consulting Psychologists Press. 1981.
Moss, F.A.; Hung, T.; and Omwake, K. Social Intelligence Test. Montreal, CA: Institute of Psychological Research, Inc. 1990.
National Commission on Correctional Health Care (NCCHC). Standards for Health Services in Juvenile Detention and Confinement Facilities. Chicago: NCCHC,. 1992.
National Highway Traffic Safety Administration. Assessment of Classification Instruments Designed To Detect Alcohol Abuse. Washington, DC: National Highway Traffic Safety Administration. 1988.
National Institute on Alcohol Abuse and Alcoholism. Screening for alcoholism. Alcohol Alert. 1990;8(PH285):1-4.
National Institute on Alcohol Abuse and Alcoholism. Assessing Alcohol Problems: A Guide for Clinicians and Researchers. NIAAA Treatment Handbook Series, Number 4. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism. 1995.
National Institute on Drug Abuse. Evaluation Instruments for Drug Abuse Adolescents and Adults. Rockville, MD: National Institute on Drug Abuse. 1992.
National Institute on Drug Abuse. Monitoring the Future Study. Rockville, MD: National Institute on Drug Abuse. 1996.
Newcomb, M.D., and Bentler, P.M. Substance use and abuse among children and teenagers. American Psychologist. 1989;44:242-248.
Oetting, E.R., and Beauvais, F. Common elements in youth drug abuse: Peer cluster and other psychological factors. In: Peele, S., ed. Visions of Addiction: Major Contemporary Perspectives on Addiction and Alcoholism. Lexington, MA: Lexington Books. 1987.
Oetting, E.R., and Beauvais, F. Adolescent drug use: Findings of national and local surveys. Journal of Consulting and Clinical Psychology. 1990;58(4):385-394. [pmid: 2212174].
Oetting, E.R.; Beauvais, F.; Edwards, R.; and Waters, M. The Drug and Alcohol Assessment System. Fort Collins, CO: Rocky Mountain Behavioral Sciences Institute. 1984.
Olson, D.H.; McCubbin, H.I.; Barnes, H.; Larsen, A.; Muxen, M.; and Wilson, M. Family Inventories: Inventories Used in a National Survey of Families Across the Family Life Cycle. St. Paul, MN: Family Social Science, University of Minnesota. 1982.
Orvaschel, H.; Puig-Antich, J.; Chambers, W.; Tabrizi, M.A.; and Johnson, R. Retrospective assessment of prepuberty major depression with the Kiddie-SADS-E. Journal of the American Academy of Child Psychiatry. 1982;21:392-397.
Rahdert, E.R., ed. The Adolescent Assessment/Referral System Manual. DHHS Publication No. (ADM) 91-1735. Rockville, MD: U.S. Department of Health and Human Services, ADAMHA, National Institute on Drug Abuse. 1991.
Rogers, R., and Cashel, M.L. Evaluation of adolescent offenders with substance abuse: Validation of the SASSI with conduct-disordered youth. Criminal Justice and Behavior, in press.
Rosenberg, M. Society and the Adolescent Self-Image. Princeton, NJ: Princeton University Press. 1965.
Reich, W.; Welner, Z.; Taibleson, C.; and Kram, L. The DICA-R Training Manual. St. Louis, MO: Washington University School of Medicine. 1990.
Ridley, T.D., and Kordinak, S.T. Reliability and validity of the Quantitative Inventory of Alcohol Disorders (QIAD) and the veracity of self-report by alcoholics. American Journal of Drug and Alcohol Abuse. 1988;14(2):263-292. [pmid: 3177342].
Riskind, J.H.; Beck, A.T.; Berchick, R.; Brown, G.; and Steer, R.A. Taking the measure of anxiety and depression: Validity of the reconstructed Hamilton Rating Scale. Journal of Nervous and Mental Diseases. 1987;175:474-479.
Rounsaville, B.J.; Weissman, M.M.; Wilber, C.; and Kleber, H.D. Identifying alcoholism in treated opiate addicts. American Journal of Psychiatry. 1983;140:764-766.
Russell, C.S. "The systems approach to family study." Unpublished manuscript, Kansas State University. 1977.
Schinka, J.A. Health Problems Checklist. Odessa, FL: Psychological Assessment Resources. 1984.
Schinke, S.; Cole, K.; Diaz, T.; and Botvin, G.J. Developing and implementing interventions in community settings. Journal of Child and Adolescent Substance Abuse. 1997;6(3):49-63.
Schuessler, K.F. Measuring Social Life Feelings. San Francisco: Jossey-Bass. 1982.
Shedler, J., and Block, J. Adolescent drug use and psychological health. American Psychologist. 1990;45:612-630.
Simpson, D.D. Drug Abuse Treatment for AIDS-Risks Reduction (DATAR): Forms Manual. Fort Worth, TX: Institute of Behavioral Research, Texas Christian University. 1990.
Simpson, D.D., and McBride, A.A. Hispanic Journal of Behavioral Sciences. Newbury Park, CA: Sage Publications. 1991.
Skinner, H. Self-report instrument for family assessment. In: Jacob, T., ed. Family Intervention and Psychopathology: Theories, Methods, and Findings. NY: Plenum. 1987.
Skinner, H.A., and Sheu, W.J. Reliability of alcohol use indices: The lifetime drinking history and the MAST. Journal of Alcohol Studies. 1982;43:1157-1170.
Skinner, H.; Steinhauer, P.; and Santo-Barbara, J. The family assessment measure. Canadian Journal of Community Mental Health. 1983;2:91-105.
Spanier, G.B. Measuring dyadic adjustment: New scales for assessing the quality of marriage and similar dyads. Journal of Marriage and the Family. 1976;38:15-28.
Spanier, G.B., and Thompson, L.A. A confirmatory analysis of the Dyadic Adjust scale. Journal of Marriage and the Family. 1982;44:731-738.
Spitzer, R.L., and Williams, J.B. Structured Clinical Interview for DSM-III-R. New York: Biometrics Research Department, New York State Psychiatric Institute. 1987.
Spitzer, R.L.; Williams, J.B.; Gibbon, M.; and First, M.B. Structured Clinical Interview for DSM-III-R. Washington, DC: The American Psychiatric Press. 1990.
Stinchfield, R.D. Reliability of adolescent self-reported pretreatment alcohol and other drug use. Substance Use and Misuse. 1997;32:425-434.
Substance Abuse and Mental Health Services Administration (SAMHSA), Center for Substance Abuse Treatment. Treatment for alcohol and other drug abuse: Opportunities for coordination. DHHS Publication No. (SMA) 94-2075. Rockville MD: Substance Abuse and Mental Health Services Administration. 1994.
Swaim, R.C.; Oetting, E.R.; Edwards, R.W.; and Beauvais, F. Links from emotional distress to adolescent drug use: A path model. Journal of Consulting and Clinical Psychology. 1989;57(2):227-231. [pmid: 2708609].
Szapocznik, J.; Perez-Vidal, A.; Brickman, A.L.; Foote, F.H.; Santisteban, D.; Hervis, O.; and Kurtines, W. Engaging adolescent drug abusers and their families in treatment: A strategic structural systems approach. Journal of Consulting and Clinical Psychology. 1988;56(4):552-557. [pmid: 3198813].
Tarter, R.E. Evaluation and treatment of adolescent substance abuse: A decision tree method. American Journal of Drug Alcohol Abuse. 1990;16(1 and 2):1-46.
Toborg, M.A.; Levin, D.R.; Milkman, R.H.; and Center, L.J. Treatment Alternatives to Street Crime: (TASC) Projects: National Evaluation Program, Phase I Summary Report. Washington, DC: National Institute of Law Enforcement and Criminal Justice. 1976.
Turner, C.F.; Ku, L.; Rogers, S.M.; Lindberg, L.D.; Pleck, J.H.; and Sonenstein, F.L. Adolescent sexual behavior, drug use, and violence: increased reporting with computer survey technology. Science. 1998;280(5365):867-873. [pmid: 9572724].
Ware, J.E. Scales for measuring general health perceptions. Health Services Research. 1976;11(4):396-415. [pmid: 1030696].
Ware, J.E. General Health Rating Index. In: Wenger, N.K.; Mattson, M.E.; Furberg, C.D.; and Elinson, J., eds. Assessment of Quality of Life in Clinical Trials of Cardiovascular Disease. NY: Le Jacq Publishing. 1984.
Ware J.E.; Manning, W.G.; Duan, N.; Wells, K.B.; and Newhouse, J.P. Health status and the use of outpatient mental health services. American Psychologist. 1984;39(10):1090-1100. [pmid: 6507983].
Weissman, M.M.; Wickramaratne, P.; Warner, V.; John, K.; Prusoff, B.; Merikangas, K.; and Gammon, D. Assessing psychiatric disorders in children: Discrepancies between mothers' and children's reports. Archives of General Psychiatry. 1987;44:747-753.
Welner, Z.; Reich, W.; Herjanic, B.; Jung, K.; and Amado, K. Reliability, validity, and parent-child agreement studies of the Diagnostic Interview for Children and Adolescents (DICA). Journal of American Academic Child Psychiatry. 1987;26:649-653.
Winters, K.C. The need for improved assessment of adolescent substance involvement. Journal of Drug Issues. 1990;20(3):487-502.
Winters, K.C. Assessment of Adolescent Alcohol and Other Drug Abuse: A Handbook. Los Angeles, CA: Western Psychological Services. 1994.
Winters, K.C., and Henly, G.A. Personal Experience Inventory Test and Manual. Los Angeles, CA: Western Psychological Services. 1989.
Winters, K.C.; Latimer, W.W.; Stinchfield, R.D. DSM-IV criteria for adolescent alcohol and cannabis use disorders. Journal of Studies on Alcohol. in press.
Witherspoon, A.D.; deValera, E.K.; and Jenkins, W.O. The Law Encounter Severity Scale (LESS): A Criterion for Criminal Behavior and Recidivism. Rehabilitation Research Foundation, Grant No. 21-01-73-38, Manpower Administration. Tuscaloosa, AL: Behavior Science Press. 1973.