# Consensus Panel

Chair
- Gary Field, Ph.D.
- Administrator
- Counseling and Treatment Services
- Correction Programs
- Oregon Department of Corrections
- Salem, Oregon

Workgroup Leaders
- Robert B. Aukerman, M.S.W.
- Program Services Consultant
- Littleton, Colorado
- Karen Carruth, M.S.
- Quality Assurance Manager
- Substance Abuse Treatment Program
- Program and Services Division
- Texas Department of Criminal Justice
- Austin, Texas
- Dorothy Lockwood, Ph.D.
- Consultant
- Newark, Delaware
- Juan Martinez, M.A.
- Assistant Chief
- Adult Probation Department
- Bear County Community Supervision and Corrections Department
- San Antonio, Texas
- Roger H. Peters, Ph.D.
- Associate Professor
- Department of Mental Health Law and Policy
- Louis de la Parte Florida Mental Health Institute
- University of South Florida
- Tampa, Florida
- Elizabeth A. Peyton
- Executive Director
- National TASC
- Silver Spring, Maryland

Panelists
- Elaine Abraham
- Consultant
- National City, California
- Margaret K. Brooks, Esq.
- Consultant
- Montclair, New Jersey
- Matthew A. Cassidy
- Criminal Justice Coordinator
- Programming Planning and Research
- Phoenix House Foundation, Inc.
- New York, New York
- Barbara Hanson Treen, M.A.
- Executive Director
- WomenCare, Inc.
- Commissioner, NYS Division of Parole (ret.)
- New York, New York
- Michael D. Link
- Assistant Chief
- Division of Programming Planning
- Ohio Department of Alcohol and Drug Addiction Services
- Columbus, Ohio
- Charles David Mitchell
- Criminal Justice Specialist
- Network Coordination
- Community Partnership of Southern Arizona
- Tucson, Arizona
- Dennis Schrantz
- Consultant
- Wayne County Department of Community Justice
- Detroit, Michigan
- Beth Weinman
- National Drug Abuse Programs Coordinator
- Federal Bureau of Prisons
- Washington, D.C.