# Chapter 1—Introduction

On any given day, some 1.7 million men and women are incarcerated in Federal and State prisons and local jails in the United States, and a recent study suggests that more than 80 percent of them are involved in substance use. In 1996 alone, taxpayers spent over $30 billion to incarcerate these individuals -- who are the parents of 2.4 million children. Put another way, one of every 144 American adults is behind bars for a crime in which substances are involved (The National Center on Addiction and Substance Abuse at Columbia University [CASA], 1998).

By a variety of measures, it is clear that substance use disorders disproportionately affect incarcerated Americans (Reuter, 1992; CASA, 1998; Federal Bureau of Prisons, 1997). Yet this population is significantly undertreated: Although prison substance use disorder programs annually treat more than 51,000 inmates, this figure represents less than 13 percent of the offender population identified as needing treatment. Studies also indicate that (with the exception of detoxification) most offenders have never received treatment in the community (Lipton et al., 1989; Peyton, 1994). Clearly, the majority of individuals in the criminal justice system in need of substance use disorder treatment are not receiving services -- either while they are incarcerated or after release to the community.

Providing substance use disorder treatment to offenders is good public policy. Recent research shows that punishment is unlikely to change criminal behavior, but substance use disorder treatment that also addresses criminal behavior can reduce recidivism (Andrews, 1994). Inmates with substance use disorders are the most likely to be re-incarcerated -- again and again -- and the length of their sentences continually increases. The more prior convictions an individual has, the more likely he has a substance use disorder. In State prisons, 41 percent of first offenders have used drugs, compared to 63 percent of inmates with two prior convictions and 81 percent of inmates with five or more prior convictions. Half of State parole and probation violators were under the influence of drugs, alcohol, or both when they committed their new offense. State prison inmates with five or more prior convictions are three times more likely than first-time offenders to be regular crack cocaine users (CASA, 1998). Offenders with substance use disorders not only crowd the nation's prisons, they are also responsible for a disproportionate amount of crime and for relatively violent crime. Compared to offenders who do not use drugs, drug-using "violent predators" commit many more robberies, burglaries, and other thefts (Chaiken, 1986).

However, offenders who have completed substance use disorder treatment during incarceration are still at great risk for relapse and recidivism when released. They need a variety of services to maintain sobriety during their transition from the institution to the community. This chapter provides an overview of the benefits of those transitional services. It also discusses obstacles to implementing such services and provides strategies for overcoming these obstacles. Finally, models for transitional services are described.

## Benefits of Offender Treatment

### Treatment During Incarceration

Some incarcerated offenders enter treatment for the same reasons as those "on the outside": They want to stop using substances and need help. Others, however, may have different motivations: boredom, the desire to improve their chances for parole, a wish to escape the violent culture of general population, or some combination of the above. Others may be mandated to treatment by the courts. Surprisingly, research shows that once an offender begins treatment, outcomes are not affected by the reasons for entering treatment (Leukefeld and Tims, 1988). A certain proportion of those who undergo treatment within the institution will succeed if supervised closely (Anglin and McGlothlin, 1984; Petersilia et al., 1992). Other key findings on the effectiveness of substance use disorder treatment within correctional institutions include the following:

- Prerelease therapeutic communities have shown high rates of success among inmates studied (Wexler et al., 1988; Field, 1989).
- Involvement in substance use disorder treatment is associated with decreased criminal recidivism. Improvements have been seen in rates of rearrest, conviction, reincarceration, and time to recidivate (Field, 1995a; Inciardi, 1996; Peters et al., 1993; Swartz et al., 1996; Wexler et al., 1990).
- Involvement in substance use disorder treatment is associated with decreased substance use and relapse and other health-related outcomes (Inciardi, 1996; Martin et al., 1995; Wexler et al., 1990).
- Duration of correctional substance use disorder treatment is associated with positive treatment outcomes. Research has shown that, up to a point, longer lengths of treatment are more effective than shorter lengths of treatment for substance-using offenders (Swartz et al., 1996; Wexler et al., 1992).
- Involvement in substance use disorder treatment, such as prison-based therapeutic communities, is associated with successful parole outcomes (including reductions in parole revocations) (Field, 1989; Wexler et al., 1992).
- Inmates involved in substance use disorder treatment had reduced rates of re-arrest and relapse when compared with inmates who did not participate (Federal Bureau of Prisons, 1998).

### Treatment During Transition To the Community

Service systems should provide offenders with appropriate treatment, since no treatment is likely to lead to continued drug use and crime. Treatment that stops when the offender is released, however, may not be enough. Release presents offenders with a difficult transition from the structured environment of the prison or jail: Despite the hardships endured "inside," they at least knew what to expect. Many offenders are released with no place to live, no job, and without family or social supports. They often lack the knowledge and skills to access available resources for adjustment to life on the outside, all factors that significantly increase the risk of relapse and recidivism (Leshner, 1997). The positive effects of substance use disorder treatment within correctional institutions may diminish once the offender moves out of the institutional environment unless followup care is provided in the community (Martin et al., 1995; Peters et al., 1992; ; Swartz et al., 1996).

The benefits of treatment during the transition from incarceration to the community are substantiated in several recent studies. In a study of drug offenders in Delaware, offenders who participated in 12 to 15 months of treatment in prison and another 6 months of treatment in the community were more than twice as likely to be drug-free 18 months after release as those who had only the prison treatment. Those offenders were also arrested much less in the year and a half following release (Inciardi, 1996). A similar study in California had comparable results (Wexler, 1996). Continuity of care from the institution to the community is associated with positive outcomes for prevention of relapse and criminal recidivism in other research as well (Swartz et al., 1996; Wexler et al., 1990).

A demonstration program in the Oregon Department of Corrections reduced re-arrest rates and conviction rates among inmates participating in a transition program (Field and Karecki, 1992). This program emphasized transition from the institution and treatment in the community, rather than providing intensive treatment within prisons and jails, along with a postrelease aftercare program.

## Why Continuity of Treatment?

Because substance use disorders are long-term, recurring illnesses, continuity of treatment is important for everyone. Studies show that the most effective treatment lasts at least 3 months, and outcomes improve with additional time in treatment. This is true for all treatment modalities and particularly for treatment of offenders (Hubbard et al., 1989; Simpson, 1984; Wexler et al., 1988). Continuity is especially important for someone leaving a correctional institution. The offender may be so acclimated to a highly structured correctional environment that everyday decisionmaking in the community is overwhelming. Many addicted offenders, like individuals with other disorders, have particular trouble transferring learning from one setting to another, so that many of the gains made in treat-ment are lost unless there is continuity of care.

In short, the offender is vulnerable to relapse into a substance use disorder and crime during the early release period. Without coordination between institutional treatment and community-based treatment, offenders are likely to relapse and return to criminality. At the most basic level, continuity of treatment consists of communication and information sharing between institutional treatment and release services personnel, community supervision staff (parole or postprison supervision), and community treatment staff. This information sharing and planning needs to take into account all the ancillary services the individual needs.

Continuity makes sense not just for offenders being released from jails and prisons, but in the context of the entire criminal justice system. The fragmentation of the various functions -- arrest, diversion, conviction, probation, revocation, jail, prison, and postprison supervision -- undermines the effects of treatment and of other aspects of offenders' rehabilitation. Offenders, particularly repeat offenders, often have antisocial personality disorders and may exploit any gap in supervision or monitoring. Any break between treatment in prison and treatment in the community is an invitation to relapse for such offenders. Ineffective continuity diminishes treatment gains, wastes treatment resources, and endangers the community.

## Obstacles to Effective Postrelease Transitions

Treatment continuity from the institution to the community can mean the difference between a career criminal and a productive member of society. Despite its importance, the obstacles to continuity of treatment are substantial. Most barriers stem from the structure of public sector systems, such as fragmentation of the criminal justice system, community providers' lack of attention to offender issues, and funding barriers. To overcome these obstacles, corrections and treatment systems need to clearly identify and understand them. Key obstacles are listed below; recommendations for overcoming them are below.

### Lack of System Coordination

The criminal justice system is not a discrete, well-coordinated system, but rather a cluster of independent agencies and entities with separate justice responsibilities. Of those entities—law enforcement agencies, bonding authorities, jails, pretrial release agencies, courts, probation agencies, community-based service providers, prisons, and parole agencies -- some may collaborate closely, while others function independently. Most operate under separate funding streams, with differing organizational missions that may or may not share philosophical orientations toward public safety and offender rehabilitation.

An offender's tour through the criminal justice system may include encountering the police when she is arrested, spending time in jail before or during trial, being reviewed for treatment needs by the court before or after sentencing, being diverted from prison to probation, having probation revoked and being sent to prison, and then being placed on parole following a prison sentence. Each step may involve a different agency. The Criminal Justice Treatment Planning Chart (Center for Substance Abuse Treatment [CSAT], 1993) provides a detailed guide to both treatment intervention opportunities and places where an offender could fall between the cracks within the typical criminal justice system.

This fragmentation inhibits transfer of information about the offender and results in duplication of some services, such as assessment, and a gap in the continuity of other services, such as case management and treatment service delivery. In many jurisdictions, institutional programming is run by an executive agency, while probation may be part of the courts. Even when all correctional interventions are part of the same administrative agency, the gaps between institutional and non-institutional services can be significant. Legal issues, particularly confidentiality, may keep information out of some transition team members' hands.

Unfortunately, the gaps in information lead to a lack of accountability for the offender upon release or transfer. Both the criminal justice and treatment systems need as much information as possible about an individual in order to ensure continuity of care; each should take advantage of the increased technical capabilities for automated information systems.

As the number of substance-using offenders escalates, and the health and social service systems that must be accessed upon release become increasingly complex, interagency linkages between correctional, health, and substance use disorder treatment systems are critical. Staff from all systems should look for opportunities to advocate for clients by brokering among different systems, facilitating immediate treatment based on periodic assessments, and learning methods for system collaboration.

#### Unclear lines of authority and responsibility

Every member of the transition team must understand the urgency of continuing treatment immediately following release to prevent relapse or recidivism. Prison and jail officials should coordinate release of offenders with openings in treatment programs so the offender has support in the stressful period following release. Something or someone -- possibly an offender tracking system or a boundary spanner (discussed below) -- is needed to ensure that the link between treatment in the institution and the community actually takes place.

Treatment providers often deal only with substance use disorder issues, but may not play a role in other practical needs, such as facilitating the offender's relationship with the probation or parole officer. If an offender misses a curfew because a group program runs long, and if the treatment provider does not understand the supervision conditions, she may be unwittingly involved in the offender violating parole. Joint staffing, collaborative planning, and policy development as well as staff cross-training can minimize these kinds of problems.

#### Different expectations

Significant differences in philosophy and approach between treatment settings in the institution and in the community can make transition to community treatment very difficult. The treatment approaches and client expectations of a community-based system may differ dramatically from a residential treatment program in a prison, jail, or other institution. Offender clients who are newly released from incarceration may be seen as noncompliant, when they are actually confused about expectations in the new setting. Offenders may not have much recent practice in personal accountability or decisionmaking because they were so strictly controlled in the institution, and many offenders have trouble generalizing coping skills learned in the institutional setting. They also may take advantage of service providers. While no generalization applies to every person who is incarcerated, a major part of jail and prison culture is "working the system." Community providers should not prejudge offender clients, but they should be alert to the possibility that the client may well manipulate and lie to them.

### Lack of Attention to Offender Issues by the Community Service System

The criminal justice population contains many who need substance use disorder treatment, yet within most community programs few specialized staff are assigned to meet offenders' needs. This is in part due to the fact that State and local substance use disorder treatment agencies have not always identified offenders as a priority population, and those agencies that provide community supervision do not always fund treatment services during probation or parole. Though offenders remain an underserved population, national, State, and local efforts have improved community treatment responsiveness to offender populations during recent years.

Another problem area may be that program licensing and State credentialing standards do not take into account the needs of the offender population. Although recently, a criminal justice treatment professional certification process was developed by the Certification Board for Addiction Professionals of Florida and the International Certification and Reciprocity Consortium. Counselors sometimes provide treatment services without appropriate supervision or monitoring. One obstacle to effective treatment may be the policy of some programs to restrict the hiring of exoffenders as treatment counselors. Such staff members can improve a program, because they may relate more readily to the needs of these clients than those whose background differs substantially from the population served.

### Funding Complications

As with most systems relying on funding from the public sector, both criminal justice and substance use disorder systems experience financial difficulties due to disconnected funding streams and competition for limited funds. Offenders making the transition from the correctional system to substance use disorder treatment in the community face an additional obstacle, in that they need services from both systems yet may not fit readily into either funding category. Available dollars are earmarked for either institutional or community services, but not for coordination between the two. Funding streams typically flow to specific divisions of social service agencies and are available only for a narrowly defined population. Prison services are usually State-funded, while community services are often county-funded. Some funding sources, including Medicaid, cease when the recipient enters prison. Ironically, funding available from some Federal agencies is not used because the population defined as needing it cannot get access in the current system.

Managed care organizations are increasingly involved in treatment decisions and may not agree with the community treatment plans for the offender. Managed care representatives may regard institution treatment as sufficient or assume that an offender who has been abstinent throughout incarceration does not need treatment. Managed care decisionmakers also may simply opt for a lower level of care than is deemed necessary by corrections or local treatment staff. New York requires managed care organizations (MCOs) to cover court-ordered offenders who may not meet the "medical necessity" criteria of the MCO. New York is currently the only State with such a law, even though many in the justice system consider public safety a more relevant treatment criterion than medical necessity.

The lack of funding for institutional programs is particularly problematic in small, rural jails and in some State prison systems. For example, a nationwide survey found that only 9 percent of small jails (fewer than 50 beds) had a funded substance use disorder treatment program, as compared to 60 percent of jails with more than 2,000 beds (Peters et al., 1992). Nor is there enough funding to create the capacity for needed community and institutional services, or for special populations such as women, women with children, and offenders with mental illness. Services are sometimes discontinued as offenders are released from jail or prison because there is no case manager to advocate for the offender. Offenders are put on waiting lists or do not receive appropriate treatment. This in turn leads to poor retention in treatment and negative outcomes (e.g., relapse or recidivism).

Typically, the only treatment services that are reimbursable in the community involve direct contact with the client, such as individual counseling, group therapy, and assessments. This is true whether the funding entity is a single State agency, a managed care plan, or Medicaid. However, what will be paid for is not necessarily what clients need. Those services for which community treatment programs are reimbursed, and areas that are the focus of performance evaluations, are not necessarily the services needed by offenders making a transition from institutional settings. For example, a significant amount of time must be spent interacting with various agencies to create linkages on behalf of the offender, yet such case management services often are not reimbursable.

Funds are rarely targeted specifically for transitional services, although innovative programs are being conducted now in Texas, Delaware, Oregon, California, and New York. The Federal prison system included a transition component in its 1989 program design, and Congress has funded this national transitional effort. Clear articulation of the public safety benefits of specific transition services helped the Federal system obtain this funding. Some jurisdictions are beginning to capitalize on the investment made in institutional treatment by supporting specific community-based services to promote continued or ongoing recovery.

For example, since August 1996, the New York State Division of Parole has channeled funding to the State Office of Alcoholism and Substance Abuse for contracts with local treatment agencies which agree to admit offenders on a priority basis. Under the agreement, the agencies also provide enhanced case management services to people released from the Willard Drug Treatment Campus (DTC). Willard DTC is a State-run, 850-bed, licensed treatment facility for substance-using, nonviolent felons. Payments to providers are performance-based.

### Coordination of Sentencing and Treatment

Whenever possible, treatment should be structured to fit within the sentence imposed by the court and, conversely, sentences should be structured to accommodate the treatment needs of the offender. The latter requirement can take several forms: Sentences can be structured so that assessments are ordered, and the defendant must follow the recommendations for treatment. In some jurisdictions, the court will modify a sentence to accommodate treatment participation after the initial imposition.

The legal system is structured to determine guilt or innocence and the primary emphasis of the court is on public safety—typical presentence and probation reports focus on risk to the community and the legal issues surrounding the defendant. Although courts have no legal obligation to attend to the substance use disorder treatment needs of offenders, some have recently taken a proactive role, recognizing that addressing substance use disorders can reduce further criminal activity and enhance public safety. The proliferation of treatment drug courts, offender-dedicated treatment programming, and alternative sentencing that includes treatment are examples of this trend.

For such programs to work, judges must be given the information they need to mandate treatment participation, particularly the need for and availability of treatment. Prior to any treatment mandate, the court should receive the results of a thorough substance use disorder assessment of the offender, performed by a qualified professional. Mandating treatment without such a qualified assessment may be seen (understandably) as retribution or punishment. Judges will also need clinical guidance in order to shape the appropriate and specific treatment interventions. Inappropriate placement in a jail or prison program, therapeutic community, or community treatment program can contribute to dropout, lack of service provision, or wasted resources. Judges also need to follow through with swift and certain sanctions for offender noncompliance.

With the advent of new criminal justice initiatives such as the Treatment Alternatives to Incarceration Program in Texas, judges can obtain more information to make treatment recommendations in their sentences.

Judges can play a critical role in the treatment of offenders by crafting sentences that enable or require treatment participation, by responding when there is a crisis or change in circumstances that requires additional treatment or supervision interventions, and by making appropriate accommodations when the offender meets treatment goals. Such judicial oversight is featured in various treatment drug courts and programs, such as CSAT's Juvenile/Criminal Justice Treatment Networks, Birmingham's Breaking-the-Cycle, and Treatment Alternatives for Safe Communities (TASC). In treatment drug court programs, supervision, treatment, and case management services are linked to the court, with individual oversight of each offender provided by a judge. Depending on the jurisdiction, offenders participate in these programs in lieu of or as part of a criminal sentence. In treatment drug courts, judges hold special "status hearings" to monitor the progress of offenders in treatment throughout their stay in the program.

In New York, the Brooklyn District Attorney's office took a leadership role in 1990 by beginning a program called Drug Treatment Alternative to Prison for defendants facing mandatory prison sentences, thus giving the prosecutors and judiciary a mechanism to sentence prison-bound nonviolent drug offenders to residential treatment, usually a therapeutic community. The program has been experiencing about a 70 percent retention rate in treatment since its inception. Six counties in New York State are now using this model. TASC is also used in some of these counties to assess, refer, and case manage.

Offenders are significantly more likely to continue in treatment after release if they are placed under community supervision (Hubbard et al., 1989) with conditions specifying involvement in treatment. While transition planning benefits all offenders, it is particularly important to offenders who need substance use disorder treatment.

### Recommendations for Overcoming Obstacles

#### Integrating systems

- View the offender's problems as the responsibility of both systems, and the offender's success as benefiting both systems.
- Make planning systems-wide, in local jurisdictions as well as at the State level.
- Establish and maintain a cross-system criminal justice/substance use disorder treatment planning body.
- Initiate joint case staffing.
- Establish protocols for sharing all information relevant to the offender's case while meeting confidentiality and privacy requirements.
- Cross-train staff.
- Create contract provisions that provide incentives for agencies to work together toward good outcomes (performance-based contracting).
- Coordinate systems that have supporting functions, such as welfare and family services departments.
- Community treatment providers should establish contact with substance-using offenders before they are released to establish trust and rapport.
- Prepare individual contracts specifying treatment appointments, frequency of meetings with the parole officer, frequency of urine tests, and vocational expectations, so that all requirements and goals are stated in one written agreement.
- Establish criminal justice monitoring in the community through the use of split sentences, work furlough programs, probation, or other options that create a transitional setting before full re-entry into the community.
- Provide offenders with incentives to engage in voluntary treatment.
- In the absence of traditional parole, the jurisdiction and the State should develop alternative strategies for providing structure, accountability, and monitoring such as postprison supervision.
- Designate a case manager, mentor, or boundary spanner to oversee the transition from the institution to the community. This person could perform a range of duties, from acting as a liaison between systems to picking up the offender upon release and taking her to a treatment program.

#### Increasing awareness of offenders' needs

- Develop specialized services and programs serving the multiple needs of offenders.
- Publicize the need for services at the State level and encourage their inclusion in treatment, criminal justice, and health and social services planning documents at both State and local levels.
- Offer outcome research demonstrating the positive effects of transitional services to funders.
- Recruit and develop staff with special expertise treating offenders.
- Examine State licensing and certification processes/standards to ensure appropriate staffing and programming models specific to offenders.
- Work toward more comprehensive system integration, including
  - Co-location of treatment and community supervision services
  - Joint planning
  - Joint case management

#### Obtaining and simplifying funding

- Correctional institutions should fund, at a minimum, substance use disorder screening, assessment, and prerelease planning, unless offenders are moved to transitional institutions on the basis of treatment needs.
- The following agencies should consider sharing resources to provide transition services:
  - Corrections and treatment
  - Probation, parole, and treatment
  - Child protective services and treatment
  - Social services and treatment
  - Treatment providers from different programs
  - Managed care plans
- These entities should look for nontraditional sources of funding, such as
  - Department of Housing and Urban Development
  - Department of Veterans' Affairs
  - Foundations
  - Department of Labor
  - Local monies
- Establish the activities of boundary spanners or case managers as a billable service.
- Write performance-based contracts that base reimbursement on realistic outcomes, such as engagement in transition services and successful reintegration in the community. Other measures can include reduction of drug use and criminal activity, financial stability, finding suitable housing, or reaching a higher educational level.

#### Coordinating sentence and treatment

- Both the institution and the community should attempt to accommodate the treatment needs of offenders, regardless of sentence length.
- Develop a variety of institutional treatment tracks for offenders with varying lengths of stay.
- Keep treatment plans flexible enough to respond to offenders' needs; devise a system for modifying a sentence based on treatment progress and other compliance measures.
- Structure sentences so that services, supervision, sanctions, and rewards encourage compliance.
- Encourage development of more court-based services, such as presentence investigation services through local probation offices, to help identify offenders who would benefit from treatment services (both inside and outside the institution), and to determine the duration of treatment needed and the type of treatment setting needed.
- Educate judges, probation officers, and community supervision staff (in part with pretreatment reports) about the use of split sentences that require both institutional and community treatment.

## Program Strategies

Three basic types of program models are used to provide transitional services for offenders being released: outreach, reach-in, and third party. In an outreach model, the correctional institution designates staff to make linkages to appropriate services in the community, while a reach-in model places the initiation of transitional services with the community programs. These models are not rigidly structured, nor are they mutually exclusive. They have many elements in common (see Figure 1-2). The ideal program uses components of each, so that the institution can identify services in the community at the same time the providers in the community initiate treatment and transition services prior to release. A variation on these two options that works well in some jurisdictions is contracting with a third-party entity to coordinate some or all transitional services.

### Institution Outreach

In this model, a member of the institution's staff initiates linkages with agencies and services beyond the institution. Among the services that require coordination are community substance use disorder treatment and other social services, parole or postprison supervision, and work release programs.

#### Key components

The primary responsibility for success of the transition lies with the case manager (or those who are collectively providing case management services). In an ideal situation, this function is assigned to a designated staff person. That person is responsible for services as the client moves from incarceration to the community.

The institution can support and foster outreach activities and prioritize followup of offender services. Institution services can also provide resources to ensure that the offender is engaged in treatment and that the services being received are appropriate.

The case manager should not be confined to making phone calls and sending letters from the institution, but should have face-to-face contact with the representatives of service agencies. Although clinical training is quite useful, other important skills for case managers include

- Ability to leave the institution to develop community transition networks
- Familiarity with community resources and the systems within which they operate
- Understanding of eligibility criteria for the services needed
- Ability to get the offender into the services

Equally important as these skills is a case manager's commitment to the continued recovery and improvement of the offender. The case manager may wish to develop a community resource directory to describe the range of services available and which agency can be used to link the offender to other services. He should also conduct orientations for community-based agencies in which he meets with staff providing aftercare services and describes the needs of the offender. The case manager describes the nature and approaches used in the institution treatment program. Open discussions about offender needs and the services offenders have used help gain the local treatment agencies' trust and help them become more willing to accept corrections clients.

In an ideal transition, the offender is an active participant in the entire process. Offender participation helps teach the offender responsibility and secures her "buy-in" to the services that will be critical to her adjustment and continued success in the community. In situations in which there are no resources for a dedicated case manager, a mentor or other volunteer can be assigned to assist the offender and serve as a broker in finding services. This approach has been used successfully in some localities. The relationship could begin while the offender is still incarcerated and would continue upon release, at which time the volunteer would meet with the offender and take him directly to a treatment program or meeting. The volunteer could then provide coordination functions on behalf of the offender with correctional and community staff. An institution parole officer (available in some States), with training and agency support, may also fulfill the case management function.

#### When is this model most effective?

Based on clinical experience, the Consensus Panel recommends the outreach model when case management resources are available in the institution, including necessary funding and a designated staff person to do transition planning. This model should be considered when there is an infrastructure of well-coordinated treatment services within the institution. If community treatment providers are not able to perform transitional services, the institution should take the initiative. The outreach model works best when the institution, community services, and the residence of the offender (upon release) are all in close proximity.

### Community Reach-In

Under this model, community programs assume primary responsibility for initiating treatment and transitional services before the offender's release. Staff members from the community agency "reach in" to the institution and begin the process of preparing the offender for transition and establishing necessary linkages.

#### Key components

As with the outreach model, the case management function is critical; however, in this case the person designated for this role is from the community agency rather than the institution. This person may be from a community treatment agency or may be employed by the community supervision agency. Service providers may come into the institution and conduct prerelease groups to describe the goals of treatment and the services they have to offer, both for the benefit of the correctional staff and the offender. They may also provide an orientation for offenders that helps with prerelease planning and educates the offender about what to expect. Reach-in transition should include at least one face-to-face interview involving the offender and both institution and community-based staff to determine the offender's plans after release. This interview should yield an assessment of the extent of progress made during institution treatment and the specific need for community treatment after release. These interviews should be conducted at the same time that the risk and needs assessments (discussed in Chapter 2) are completed. Given the potential conflict of interest of referring solely to one's own community agency, provider recommendations for an offender's continued treatment should be based on each client's individual treatment needs. Treatment providers should agree to utilize the full spectrum of local treatment services.

The community provider needs access to information about institution treatment participation and related activities so the foundation laid in the institution can be built upon (and not duplicated) after release. The transfer of assessment information and any treatment/release plans should occur during the prerelease planning stage. The offender's consent is needed to transfer information about treatment participation. After release, a feedback loop can communicate whether the offender made the link to treatment and describe the services being provided and the attendance and progress of the offender.

The Federal confidentiality regulations (42 Code of Federal Regulations [C.F.R.] Part 2) complicate this feedback loop, except in those instances where the feedback is to the criminal justice agency that mandated the offender's participation in treatment. In other situations, the offender must consent to the community provider sending the institution feedback. The ordinary 42 C.F.R. consent form must then be used, which means the offender can revoke the consent form (although he is unlikely to do so).

Reach-in Model Program: Single Parent Resource Center's Healthy Horizons Program

This New York State program helps female offenders in a number of prisons make the transition into the community. The program sends a staff person into the prison to conduct a workshop about issues involved in the transition process, including substance use disorder issues, housing, income, and parenting. Once the women are released, the program provides them with substance use disorder relapse prevention services, supportive group counseling, and case management services. It also helps the women reunite with their children by hosting weekly meetings where parent and child can become reacquainted after a long separation in a pleasant, nonpressured atmosphere and by arranging visits at its offices between mothers and children (for those who lost custody).

#### When is this model most effective?

Based on clinical experience, the Consensus Panel has found the reach-in model most appropriate when community providers are able and motivated to serve offender clients. Reach-in case management is most necessary when the institution lacks transition staff or resources. This model is especially appropriate for jails, because the shorter term makes rapid engagement more critical. The treatment providers have the opportunity to conduct assessments and make recommendations to the corrections staff concerning the offender's needs. In jail and prison prerelease situations, there are more incentives for the providers to reach in to the inmates, as the inmate will soon be released into the community. This model may be more difficult to implement in some prisons which have a population covering a larger geographic area. However, some programs have found reach-in by telephone (case conferences) to be effective.

### Third-Party Coordination

Third-party coordination can be a program model or a method of contracting for brokering and coordination of some or all services. It may be used with either of the models previously described (or a hybrid model that includes elements of both). When a third party is used, some coordination and case management functions are not performed by either the treatment provider or the individual responsible for supervision. Rather, an independent agency or program (such as TASC; see box below) serves as a liaison and is responsible for identifying transitional service needs, coordinating (not delivering) services, and matching offenders with these services. The third party may be from either the public or private sector. It may be particularly useful to broker for services in this way in more complex systems. Third-party models are more likely to be helpful in coordinating large systems, including multiple programs and services.

Model Third Party Entity: TASC

Treatment Alternatives for Safe Communities (TASC) serves to integrate the separate systems of criminal justice and substance use disorder treatment by identifying, assessing, and referring offenders to treatment as an alternative or supplement to justice system sanctions. TASC provides ongoing case management by monitoring the offender's compliance with justice system requirements and progress in treatment. TASC then reports that progress (or lack thereof) to the court or other supervision agency. TASC applies the leverage of the criminal justice system to encourage retention and progress in treatment. By establishing structured relationships within and between the treatment and justice systems and providing direct accountability to the court, TASC ensures ongoing support and effective communication between treatment providers and justice system professionals. The TASC "organiza-tional elements" provide a framework for effective program configuration, support for treatment to retain offenders in programs and maintain client motivation, and support for the justice system to have effective and meaningful options that meet criminal justice goals and ensure public safety. TASC "operational elements" inform meaningful and effective sentencing decisions and ensure the implementation of individually tailored sentences that involve both treatment and sanctions. TASC's system of assessment, referral to treatment, and case management ensures that the powers of the legal system are utilized to reduce both the drug use and criminal activity of drug-involved offenders. TASC is a model that can be adapted to support corrections, the courts, including drug courts, and treatment agencies. It has had success in demonstrating increased treatment retention for offender clients, as well as improved communication and coordination among criminal justice and substance use disorder authorities.

#### Key components

Rather than merely tracking the offender, the third-party contractor can provide continuous, ongoing case management to ensure that the offender enters and remains in appropriate treatment. For example, the third party may be responsible for moving the offender out of a treatment situation that is not working. This entity answers to both supervision and treatment authorities and is responsible for reporting on the offender's progress to multiple agencies, such as the court and parole authority.

#### When is use of a third party most effective?

Based on clinical experience, the Consensus Panel has concluded that a third party can be most useful when there are fragmented, disjointed services, making it difficult for either the institution or the community program to coordinate care. This approach to coordination of services is effective in filling gaps when case management services are not available, when there are no services within the institution to do transitional planning, and when little or no community supervision is available.

Model Integrated Program: Federal Bureau of Prisons

The Federal Bureau of Prisons residential substance use disorder treatment program is the flagship of the Bureau's treatment strategy. Currently, 42 Bureau of Prisons institutions operate residential treatment programs, with a combined annual capacity of nearly 6,000 inmates. The programs are 6, 9, or 12 months long and provide a minimum of 500 hours of treatment. The Bureau has a three-phase treatment curriculum that is followed in every residential program. The third phase of this treatment is the beginning of the inmate's transition from the program.

### An Integrated Transition Approach

Although each program model has its strengths, transition planning ideally involves both institution and community services in a "mixed model." Such an integrated approach provides opportunities for effective collaboration and more readily unites systems because they are forming an alliance to reach mutual goals. The systems gain a greater understanding of each other, learn a common terminology, and develop trust in each other's work.

When systems integrate their functions to provide transitional services, there is enhanced preparation for those offenders who are being released from jail. Critical service needs are more easily identified, and the offender has a better opportunity to become engaged in community treatment. Relapse prevention efforts are more likely to succeed.

Additionally, the mixed model allows systems to be more responsive to critical incidents, because monitoring and surveillance are more coordinated, there is better communication across systems, and sanctions are developed and enforced by both the criminal justice and substance use disorder treatment agencies.

Model Integrated Program: Phoenix House, New York

Phoenix House in New York is an example of the private and public sectors collaborating to offer a full continuum of treatment services for drug offenders. Since 1990, the Phoenix House/Marcy program has provided a continuum of care for drug offenders under contract with the New York Department of Correctional Services and with funding from the State Office of Alcoholism and Substance Abuse Services.