# Appendix D—Field Reviewers

- David M. Altschuler, Ph.D.
- Principal Research Scientist
- Insitute for Policy Studies
- Johns Hopkins University
- Baltimore, Maryland

- G. Dean Austin, M.A., Ed.
- Bureau Chief
- Bureau of Licensure and Support Services
- Iowa Department of Public Health
- Des Moines, Iowa

- Donna H. Caum, M.S.S.W.
- Treatment Program Consultant
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, Tennessee

- Peggy Clark, M.S.W., M.P.A.
- Behavioral Health/Medicaid Managed Care
- Health Care Financing Administration
- Baltimore, Maryland

- Daniel P. Forget, C.E.A.P.
- Director
- Bureau of Criminal Justice Services
- Central Office
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York

- Ingrid D. Goldstrom, M.Sc.
- Substance Abuse and Mental Health Services Administration
- Center for Mental Health Services
- Rockville, Maryland

- Edwin Harrison
- President
- National Commission on Correctional Health Care
- Chicago, Illinois

- Lois A. Hempen, M.S., C.A.D.C., C.R.A.D.P.
- Director
- Nearwest-Criminal Justice Programs
- Human Resources Development Institute, Inc.
- Chicago, Illinois

- Warren W. Hewitt
- Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Edwin C. Hostetter, Ph.D.
- Director of Research
- Center for Justice Initiatives
- Prison Fellowship Ministries
- Reston, Virginia

- Linda S. Janes, C.C.D.C., III
- Recovery Services Administrator
- Division of Parole and Community Services
- Ohio Department of Rehabilitation and Corrections
- Columbus, Ohio

- L. Kevin Kelly, M.Ed.
- Team Leader
- Vocational Support Service
- Safe and Drug Free Schools
- Montgomery County Public Schools
- Silver Spring, Maryland

- Dominic Lisa, M.P.H., M.A.C., C.C.J.S.
- Director Community Relations
- Community Corrections Corporation
- Roseland, New Jersey

- Richard J. Nimer, M.A.
- Bureau Chief
- Programs and Quality
- Community Corrections
- Florida Department of Corrections
- Tallahassee, Florida

- Dee S. Owens, M.P.A.
- Director
- Public and Private Sectors
- Infinity Now Consulting
- Trafalgar, Indiana

- Scott M. Reiner, M.S., C.A.C., C.C.S.
- Substance Abuse Program Supervisor
- Substance Abuse Services Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- Steven J. Shapiro
- Public Health Advisor
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Peg J. Shea, M.S.S.W., L.C.S.W., C.C.D.C.
- Program Director
- Turning Point Addiction Services
- Missoula, Montana

- Anne H. Skinstad, Psy.D.
- Substance Abuse Counseling Program
- Addiction Technology Training Center
- University of Iowa
- Iowa City, Iowa

- Judith A. Stanley
- Director of Accreditation
- National Commission on Correctional Health Care
- Chicago, Illinois

- Richard E. Steinberg, M.S.
- President/CEO
- WestCare
- Las Vegas, Nevada

- Richard T. Suchinsky, M.D.
- Associate Director, Addictive Disorders
- Department of Veterans Affairs
- Mental Health and Behavioral Sciences Services
- Washington, D.C.

- William S. Tanner, M.S.H.S., M.A.C., C.C.J.S.
- Director
- Community Alternatives
- Health Research Network
- Community Support and Counseling
- Waterville, Maine

- Robert Walker, M.S.W., L.C.S.W., B.C.D.
- Director
- Bluegrass East Comprehensive Care Center
- Lexington, Kentucky

- Nancy L. Wieman
- Mental Health, Mental Retardation
- Drug and Alcohol Programs
- County of Montgomery Court House
- Norristown, Pennsylvania

- Laura A.Winterfield, Ph.D.
- Social Science Analyst
- Office of Justice Pograms
- Department of Justice
- National Institute of Justice
- Washington, D.C.