# Appendix C — Resource Panel

- Brad Austin
- Public Health Advisor
- Treatment Operations and Review
- Division of State Programs
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Patrick Coleman
- Resident Practitioner
- Bureau of Justice Assistance
- Washington, D.C.

- Joseph Cronk
- Intern
- Pretrial Services Resource Center
- Washington, D.C.

- Ingrid D. Goldstrom, M.Sc.
- Substance Abuse and Mental Health Services Administration
- Center for Mental Health Services
- Rockville, Maryland

- Edwin C. Hostetter, Ph.D.
- Director of Research
- Center for Justice Initiatives
- Prison Fellowship Ministries
- Reston, Virginia

- Paul Molloy
- Chief Executive Officer
- Oxford House, Inc.
- Silver Spring, Maryland

- Marc Pearce
- Chief of Staff
- National Association of Drug Court Professionals
- Alexandria, Virginia

- Marie F. Ragghianti, M.P.A., M.S.
- Chief of Staff
- United States Parole Commission
- Department of Justice
- Chevy Chase, Maryland

- Steven J. Shapiro
- Public Health Advisor
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Judith A. Stanley
- Director of Accreditation
- National Commission on Correctional Health Care
- Chicago, Illinois

- Rodney D. Stewart
- Corrections Officer
- Youth Facility
- D.C. Department of Corrections
- Washington, D.C.

- Richard T. Suchinsky, M.D.
- Associate Director, Addictive Disorders
- Department of Veterans Affairs
- Mental Health and Behavioral Sciences Services
- Washington, D.C.

- Laura A. Winterfield, Ph.D.
- Social Science Analyst
- Office of Justice Programs
- National Institute of Justice
- Department of Justice
- Washington, D.C.