# Appendix B—Instruments

This appendix includes

- The Substance Use Survey (SUS)
- Adolescent Self Assessment Profile (ASAP)
- Institutional Substance Use Disorder Program Discharge Summary
- Transition Plan from the Powder River Alcohol and Drug Program
- Contacts Directory

## Substance Use Survey (SUS)

Page 1 (50 Kbytes)

Page 2 (45 Kbytes)

Page 3 (35 Kbytes)

Page 4 (48 Kbytes)

## Adolescent Self Assessment Profile (ASAP)

Page 1 (63 Kbytes)

## Sample Substance Use Disorder Program Discharge Summary

### Discharge Summary

Sample Substance Use Disorder Program Discharge Summary

DISCHARGE SUMMARY

DISCHARGE SUMMARY
Name | SID # | TDCJ #
Date of Entry | Scheduled Release Date
County of Conviction | County of Residence
Primary Counselor
Transitional Coordinator/Case Manager
Circumstances of Discharge
Identified needs and problems (from Master Treatment Plan):
Progress and Prognosis:
Resident | | Date
Primary Counselor | | Date
Transitional Coordinator/Case Manager | | Date
Senior Counselor | | Date
What are you going to do if a relapse occurs?
What type of support group(s) will you attend and where?
Will you have a sponsor? Who? Why that person?
Are you going to work the 12 steps?
How are you going to use your leisure time?
PERSONAL AFTERCARE GOALS AND OBJECTIVES
ABSTINENCE GOALS: What do I need to maintain my sobriety? (Basic Needs)
What do I need in order to continue to grow and strengthen my sobriety?
SOCIAL GOALS: What type of relationships with others do I need in order to feel I have a healthy social life that will enhance positive feelings about myself and my sobriety?
PHYSICAL GOALS: What are my specific plans for increasing my physical health?
What type of maintenance schedule will I need in order to continue the changes initiated during my treatment?
RECREATIONAL GOALS: What do I plan to do to meet my needs for fun and frolic that will not endanger my sobriety?
CREATIVE AND OTHER PERSONAL GOALS: In what areas am I creatively talented?
What are some specific projects I want to begin and complete after discharge (e.g., music, art, carpentry, auto mechanics, writing, and electronics)?
What are the steps I need to take in order to successfully initiate and complete a creative project?
NOTES/COMMENTS:

### DISCHARGE SUMMARY -- CONT

DISCHARGE SUMMARY - CONT

DISCHARGE SUMMARY -- CONT
Need | No. | Recommendations
Substance Use Disorders
Self Help Group
Housing
Educational
Vocational
Employment
Psychological
Medical/Dental
Legal
Other
Educational/Vocational Programs Completed (Dates) During Confinement | | Proposed Residence Address and Relationship | Proposed Employment
Staff comments
Resident | | Primary Counselor
Date | | Date
Transitional Coordinator/Case Manager
Distribution:; - Treatment; - Parole Officer; - Transitional Coordinator/Case Manager; - PD Case Manager

### RELAPSE PREVENTION PLAN

1. Prepare list of personal early warning signs.
2. Develop new responses to those signs.
3. Prepare list of events and high risk situations.
4. Develop list of significant others that are helpful in a relapse situation.

### PREPARE AN EMERGENCY PLAN

Call Someone:

Go Somewhere:

Keep an emergency plan in a convenient place with enough money for telephone calls, taxi fare, gasoline money, etc.

Remember that relapse is a process and not an event. The earlier that you interrupt the process, the more likely you are to be successful.

STRESSORS:

### Powder River Transition Plan

Transition Team Checklist Resident Chart

Transition Team Checklist Resident Chart

Name: | | CPMS #:
Admission Date: | | SID #:
Release Date:
Certificates:
_____ Attendance | _____ Justification Form | _____ Chart Copy
_____ Participation | _____ Justification Form | _____ Chart Copy
_____ Graduation | _____ Justification Form | _____ Chart Copy
_____ Comprehensive Continuing Care Plan
Releases: | | Tele-conference Calls:
_____ Family | | _____ Family
_____Medical | | _____Parole Officer
_____ DOC | | _____ Continuing Care Provider
_____Continuing Care Provider | | _____Employer
_____Parole Officer | | _____Other
_____(Other)
_____ Media
_____Continuing Developing Recovery Plans
_____Warning Sign Identification Card / When I experience this warning sign
_____Relapse Prevention Plan
_____Post Test
_____ Criminal First Step
_____ Other___________ | Mandatory | Electives
_____ Step Work | 1 2 3 4 5 / | 6 7 8
Transfer Summaries:
_____ Assessment
_____ Treatment
Discharge Summary:
_____ Transition
_____ CPMS Termination Form
_____ Chart Closure

### Comprehensive Continuing Care Plan

[image]

Relapse Prevention Plan

Relapse Prevention Plan

A. List the behaviors you show as warning signs as you are moving closer to using alcohol or drugs:
1.
2.
3.
4.
5.
B. List the most effective actions you can take when these signs occur:
1.
2.
3.
4.
5.
C. People who know your warning signs, and who will strongly suggest actions you can take to intervene in your relapse:
1.
2.
3.
(Resident's Signature)
(Date)
(Counselor's Signature)
(Date)

Personal Continuing Care Plan

Personal Continuing Care Plan

The quality of my sobriety will depend on how willing I am to put forth effort in the following areas:
PHYSICAL RECOVERY, PSYCHOLOGICAL RECOVERY, RELAPSE PREVENTION, SUPPORT RESOURCES, SOCIAL RECOVERY, LEISURE TIME ACTIVITIES, STRESS MANAGEMENT, and CRIMINAL THINKING ERRORS and PATTERNS.
Of course I need to break each of these areas down intosomething I can understand and FOLLOW.
For my PHYSICAL RECOVERY I must plan what I am going to do about:
My Nutrition:
Caffeine and Sugar:
Vitamins:
My Exercise Plan:
Sleep:
For my PSYCHOLOGICAL RECOVERY I need to learn to cope with emotions, especially negative feelings like anger, fear, guilt, etc.
This is what happens to me when I have these negative feelings:
Physically:
Emotionally:
My most difficult feeling to express or cope with is:
These are the ways I can deal with these feelings:
My second most-hard-to-handle feeling is:
These are the ways I can deal with these feelings:
RELAPSE PREVENTION is the next area I must take a look at and the 37 relapse warning signs.
After studying that list, I know that my 5 most important relapse warning signs are:
(1)
(2)
(3)
(4)
(5)
In my own words I describe them as: (1)
(2)
(3)
(4)
(5)
When I recognize these danger signs, this is the way I plan to handle them (unlike how I did in the past).
(1)
(2)
(3)
(4)
(5)
I know I am going to need SUPPORT RESOURCES.
My support system is:
My SOCIAL RECOVERY is probably going to be one of the most difficult things I have to do. My friends have been a big part of my life and I need to "fit in" somewhere. I have to reevaluate many relationships. I have to ask myself some important questions.
Are there people I need to avoid?
If so, who?
Where can I meet new "healthy" people?
Are there situations or places I need to avoid?
Will I allow myself to be put in places where there are alcohol or drugs?
Why or why not?
What will I do if someone brings alcohol or drugs into my house?
My LEISURE TIME ACTIVITIES are:
How often do I want to do these activities?
What new areas of recreational activities will I start in the next 6 months?
How important is it for me to enjoy myself and my family?
(EXPLAIN)
It is extremely important to me to understand and learn STRESS MANAGEMENT. Looking back, I have already covered many topics in this plan. Which of these areas are stress management techniques? (Example -- Physical Recovery, etc.)
What other stress management techniques will I use?
What are my most pronounced CRIMINAL THINKING ERRORS ?
What are my most pronounced CRIMINAL THINKING PATTERNS ?
CRIMINAL RELAPSE PREVENTION is another area I must take a look at. I know that my five most important criminal relapse warning signs are:
(1)
(2)
(3)
(4)
(5)
When I recognize these criminal relapse danger signs, this is the way I plan to handle them (unlike how I did in the past):
(1)
(2)
(3)
(4)
(5)
Looking back, what progress have I made while in treatment?
GOD, GRANT ME THE SERENITY TO ACCEPT THE THINGS I CAN NOT CHANGE, TO CHANGE THE THINGS I CAN, AND THE WISDOM TO KNOW THE DIFFERENCE.

### Transition Treatment Action Plan

Transition Treatment Action Plan

Resident Name:
Date:
I. PROBLEM #: VII SECTION #: ASpecial Needs WEEK 1-2
A.2. Case Management Plan
II. OBJECTIVE (must be timely/ measurable/ behavioral):
Within the next ( ) days, I will be able to complete a continuing care plan. The goal of this plan is to assist me to NOT return to alcohol and drug use or criminality.
III. PLAN OF ACTION (based on direct alterations of behaviors or of obstacles to change, frequency):
Target _____ Date _____
Actual ______ Date _____
Staff/Res. _____ Initials _____
1. Complete Comprehensive Continuing Care Plan (with Primary)
Give to Secretary for processing by:
2. Sign appropriate release of information (with Primary)
Prepare Relapse Prevention Plan
Turn in to Primary by:
Read in group by
Original to file by:
Obtain Release Prevention/ Transition Packet
RESIDENT SIGNATURE
DATE:
STAFF SIGNATURE
DATE:
DATE COMPLETED:
Staff's Initials
Resident's Initials
EXPLANATION FOR NON-COMPLETION OF TX OBJECTIVES:
Staff's Initials:

## Contacts Directory

### Phoenix House

PO Box 33 Utica, NY Contact: J. Smith

### Denver Juvenile Justice Integrated Network

303 West Colfax Avenue, #975 Denver, CO 80204 (303) 893-6898. Jennifer Mankey, Project Director

### Family and Corrections Network

32 Oak Grove Rd., Palmyra, VA 22963 (804) 589-3036; fax (804) 589-6520

### Center for Sex Offender Management (CSOM)

8403 Colesville Road, Suite 720 Silver Spring, MD 20910 (301) 589-9383; fax (301) 589-3505

A collaborative effort of the Office of Justice Programs, the National Institute for Corrections, and the State Justice Institute, CSOM provides a clearinghouse for issues related to sex offender programs.

### Substance Use Survey (SUS) - IA

Ken Wanberg, Th.D., Ph.D. Center for Addictions Research and Evaluation 5460 Ward Road, Suite 140 Arcada, CO 80002 (303) 421-1261

### Adolescent Self Assessment Profile (ASAP)

Ken Wanberg, Th.D., Ph.D. Center for Addictions Research and Evaluation 5460 Ward Road, Suite 140 Arvada, CO 80002 (303) 421-1261