# Appendix A -- Bibliography

Abdul-Quader, A.S.; Friedman, S.R.; Des Jarlais, D.; Marmor, M.M.; Maslansky, R.; and Bartelme, S. Methadone maintenance and behavior by intravenous drug users that can transmit HIV. Contemporary Drug Problems. 1987.
Abt Associates. Case Management with Drug Involved Arrestees. Report for National Institute of Justice and National Institute of Drug Abuse. Washington, DC: National Institute of Justice. 1995.
Alford, G.S.; Koehler, R.A.; and Leonard, J. Alcoholics Anonymous-Narcotics Anonymous model of inpatient treatment of chemically dependent adolescents: A 2-year outcome study. Journal of Studies on Alcohol. 1991;52:118-126.
Allen, M. Boot camps fail to pass muster. Governing. 1997.
Altschuler, D.M., and Armstrong, T.L. Aftercare not afterthought: Testing the IAP model. Juvenile Justice. 1996;3(1):15-22.
Altschuler, D.M. and Armstrong, T.L. Reintegrating high-risk juvenile offenders from secure correctional facilities into the community: Report on a four-state demonstration. Corrections Management Quarterly. 1997;1(4):75-83.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. Washington, DC: American Psychiatric Press, 1994.
American Society of Addiction Medicine (ASAM). Patient Placement Criteria for the Treatment of Substance-Related Disorders. 2nd ed. Chevy Chase, MD: American Society of Addiction Medicine, Inc. 1996.
Andrews, D.A. An Overview of Treatment Effectiveness: Research and Clinical Principles. Ottawa: Carleton University Department of Psychology, 1994.
Anglin, M.D., and Hser, Y.I. Treatment of drug abuse. In: Tonry, M., and Wilson, J.Q., eds. Drugs and Crime. Chicago: University of Chicago Press, 1990. pp. 393-460.
Anglin, D., and McGlothlin, W. Outcome of narcotic addicted treatment in California. In: Tims, F.M., and Ludford, J.P., eds. Drug Abuse Treatment Evaluation: Strategies, Progress, and Prospects. National Institute on Drug Abuse Research Monograph Number 51, NTIS Pub. No. 85-150365/AS. Rockville, MD: National Institute on Drug Abuse, 1984. pp. 105B128.
Bale, R.N.; Van Stone, W.W.; Kuldau, J.M.; Engelsing, T.J.J.; Elashoff, R.M.; and Zarcone, V.P. Therapeutic communities vs. methadone maintenance. A prospective controlled study of narcotic addiction treatment: Design and one-year follow-up. Archives of General Psychiatry. 1980;37:179-193.
Ball, J.C.; Lange, W.R.; Meyers, C.P.; and Friedman, S.R. Reducing the risk of AIDS through methadone maintenance treatment. Journal of Health and Social Behavior. 1988;29:214-226.
Ball, J.C., and Ross, A., eds. The Effectiveness of Methadone Maintenance Treatment: Patients, Programs, Services, and Outcome. New York: Springer-Verlag, 1991.
Barthwell, A.G.; Bokos, P.; Bailey, J.; Nisenbaum, M.; Devereux, J.; and Senay, E.C. Interventions/Wilmer:. A continuum of care for substance abusers in the criminal justice system. Journal of Psychoactive Drugs. 1995;27(1):39-47. [pmid: 7602439].
Bureau of Justice Statistics. A National Report: Drugs, Crimes, and the Justice System. Number NCJ-133652. Washington, DC: Bureau of Justice Statistics. 1992.
Bureau of Justice Statistics. Women in Prison. Number NCJ-145321. Washington, DC: Bureau of Justice Statistics, March. 1994.
Bureau of Justice Statistics. Prison and Jail Inmates at Midyear 1997. BJS Bulletin, Number NCJ-167247. Washington, DC: Bureau of Justice Statistics, January. 1998.
Center for Substance Abuse Treatment. Relapse Prevention and the Substance-Abusing Criminal Offender. Technical Assistance Publication (TAP) Series, Number 8. DHHS Pub. No. (SMA) 93-2008. Rockville, MD: U.S. Department of Health and Human Services. 1993a.
Center for Substance Abuse Treatment. Screening and Assessment of Alcohol- and Other Drug-Abusing Adolescents. Treatment Improvement Protocol (TIP) Series, Number 3. DHHS Pub. No. (SMA) 93-2009. Washington, DC: U.S. Government Printing Office. 1993b.
Center for Substance Abuse Treatment. Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 7. DHHS Pub. No. (SMA) 94-2076. Washington, DC: U.S. Government Printing Office. 1994a.
Center for Substance Abuse Treatment. Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 8. DHHS Pub. No. (SMA) 94-2077. Washington, DC: U.S. Government Printing Office. 1994b.
Center for Substance Abuse Treatment. Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series, Number 12. DHHS Pub. No. (SMA) 94-3004. Washington, DC: U.S. Government Printing Office. 1994c.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 14. DHHS Pub. No. (SMA) 95-3031. Washington, DC: U.S. Government Printing Office. 1995a.
Center for Substance Abuse Treatment. Treatment for HIV-Infected Alcohol and Other Drug Abusers. Treatment Improvement Protocol Series, Number 15. DHHS Pub. No. (SMA) 95-3038. Washington, DC: U.S. Government Printing Office. 1995b.
Center for Substance Abuse Treatment. Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol Series, Number 17. DHHS Pub. No. (SMA) 95-3039. Washington, DC: U.S. Government Printing Office. 1995c.
Center for Substance Abuse Treatment. Checklist for Monitoring Alcohol and Other Drug Confidentiality Compliance. Technical Assistance Publication (TAP), Number 18. DHHS Pub. No. (SMA) 96B3083. Washington, DC: U.S. Government Printing Office. 1996a.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, Number 23. DHHS Pub. No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office. 1996b.
Center for Substance Abuse Treatment. Substance Abuse Among Older Adults. Treatment Improvement Protocol (TIP) Series, Number 26. DHHS Pub. No. (SMA) 98-3179. Washington, DC: U.S. Government Printing Office. 1998a.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 27. DHHS Pub. No. 98-3332. Washington, D.C: U.S. Government Printing Office. 1998b.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series, Number 29. DHHS Pub. No. (SMA) 96-3249. Washington, DC: U.S. Government Printing Office. 1998c.
Center for Substance Abuse Treatment. Integrating Vocational Services With Substance Use Disorder Services. Treatment Improvement Protocol (TIP) Series, in press.
Chaiken, M.R. Crime rates and substance abuse among types of offenders. In: Johnson, B.D., and Wish, E.D., eds. Crime Rates Among Drug-Abusing Offenders: Final Report to the National Institute of Justice. New York: Narcotic and Drug Research, Inc., 1986.
Cote, G. and Hodgins, S. Co-occurring mental disorders among criminal offenders. Bulletin of the American Academy of Psychiatry Law. 1990;18(3):271B281.
Covington, S.S. A Woman's Way Through the 12 Steps. Center City, MN: Hazelden. 1994.
Covington, S.S., and Surrey, J.L. The relational model of women's psychological development: Implications for substance abuse. In: Wilsnack, R., and Wilsnack, S., eds. Gender and Alcohol. Piscataway, NJ: Rutgers University Press. 1997.
DeLeon, G. The Therapeutic Community: Study of Effectiveness, Social and Psychological Adjustment of 400 Dropouts and 100 Graduates from the Phoenix House Therapeutic Community. Rockville, MD: National Institute on Drug Abuse. 1984a.
DeLeon, G. Program based evaluation research in therapeutic communities. In: Tims, F.M., and Ludford, J.P., eds. Drug Abuse Treatment Evaluation: Strategies, Progress, and Prospects. National Institute on Drug Abuse Research Monograph Number 51, NTIS Pub. No. 85-150365/AS. Rockville, MD: National Institute on Drug Abuse, 1984b. pp. 69-87.
DeLeon, G. Therapeutic communities for addictions: A theoretical framework. International Journal of the Addictions. 1995;30(12):1603-1645. [pmid: 8557410].
DeLeon, G.; Wexler, H.K.; and Jainchill, N. The therapeutic community: Success and improvement rates 5 years after treatment. International Journal of the Addictions. 1982;17:703-747.
Department of Justice. "Inmates by Race." http://www.bop.gov/ [Accessed June 1, 1998].
Des Jarlais, D.C.; Friedman, S.R.; and Ward, T.P. Harm reduction: A public health response to the AIDS epidemic among injecting drug users. Annual Review of Public Health. 1993;14:413-450.
Dinges, N.G., and Maynard, W.S. Intercultural aspects of organizational effectiveness. In: Landis, D., and Brislin, R.W., eds. Handbook of Intercultural Training. Vol. II, Issues in Training Methodology. New York: Pergamon, 1983. pp. 50-81.
Edens, J.F.; Peters, R.H.; and Hills, H.A. Treating prison inmates with co-occurring disorders: An integrative review of existing programs. Behavioral Sciences and the Law. 1997;15: 439-457.
Federal Bureau of Prisons. Quick Facts. Washington, DC: Federal Bureau of Prisons, May. 1997.
Federal Bureau of Prisons. Triad Drug Treatment Evaluation Six-Month Report Executive Summary. Washington, DC: Federal Bureau of Prisons. 1998.
Field, G. The Cornerstone program: A client outcome study. Federal Probation. 1984;48(10):50-55.
Field, G. The effects of intensive treatment on reducing the criminal recidivism of addicted offenders. Federal Probation. 1989;53(10):51-56.
Field, G. "Turning Point alcohol and drug program (women's unit) outcome study. Addendum No. 1." Unpublished report, January 1995a.
Field, G. "Powder River alcohol and drug program outcome study. Addendum No. 2." Unpublished report, January 1995b.
Field G., and Karecki, M. Outcome Study of the Parole Transition Release Project. Oregon Department of Corrections. 1992.
Fink, E.B.; Longabaugh, R.; McCrady, B.M.; Stout, R.L.; Beattie, M.; Ruggieri-Authelet, A.; and McNeil, D. Effectiveness of alcoholism treatment in partial versus inpatient settings: Twenty-four month outcomes. Addictive Behaviors. 1985;10:235-248.
Gendreau, P. The principles of effective interventions with offenders. In: Harland, A., ed. Choosing Correctional Options That Work. Newbury Park, CA: Sage Publications, 1996.
Gerstein, D.R.; Johnson, R.A.; Harwood, H.J.; Fountain, D.; Suter, N.; and Malloy, K. Evaluating Recovery Services: The California Drug and Alcohol Treatment Assessment (CALDATA). Sacramento, CA: California Department of Alcohol and Drug Programs. 1994.
Harlow, L.L., and Anglin, M.D. Time series design to evaluate effectiveness of methadone maintenance intervention. Journal of Drug Education. 1984;14(1):53-72. [pmid: 6537443].
Harvard Medical School Health Publications. Harvard Mental Health LetterBoston: Harvard Medical School Health Publications, 1995
Hein, Hien, D., and Scheier, J. Trauma and short-term outcome for women in detoxification. Journal of Substance Abuse Treatment. 1996;13:227-231.
Hiller, M.L.; Knight, K.; Devereux, J.; and Hathcoat, M. Posttreatment outcomes for substance-abusing probationers mandated to residential treatment. Journal of Psychoactive Drugs. 1996;28(3):291-296. [pmid: 8895113].
Hoffman, N.G., and Miller, N.S. Treatment outcomes for abstinence-based programs. Psychiatric Annals. 1992;22(8):402-408.
Holt, N. Research update: Assessing correction programs for risk reduction. Perspectives. 1998.
Hubbard, R.L.; Marsden, M.E.; Rachal, J.V.; Harwood, H.J.; Cavanaugh, E.R.; and Ginzburg, H.M. Drug Abuse Treatment: A National Study of Effectiveness. Chapel Hill, NC: University of North Carolina Press. 1989.
Hubbard, R.L.; Rachal, J.V.; Craddock, S.G.; and Cavanaugh, E.R. Treatment outcome prospective study (TOPS): Client characteristics and behaviors before, during, and after treatment. In: Tims, F.M., and Ludford, J.P., eds. Drug Abuse Treatment Evaluation: Strategies, Progress, and Prospects. National Institute on Drug Abuse Research Monograph, Number 51. NTIS Pub. No. 85-150365/AS. Rockville, MD: National Institute on Drug Abuse, 1984.
Inciardi, J.A. Classification, assessment, and treatment planning for alcohol and drug-involved offenders. TIE Communique. 1993.
Inciardi, J.A. A corrections-based continuum of effective drug abuse treatment. National Institute of Justice Research Preview, June 1996.
Jolin, A. Women's life skills class boosts reintegration. Correctional Education Bulletin. 1998;1(7):1-67.
Kasl, C.D. Many Roads, One Journey: Moving Beyond the 12-Steps. New York: Harper Collins. 1992.
Landry, M. Overview of Addiction Treatment Effectiveness. Rockville, MD: Substance Abuse and Mental Health Services Administration Office of Applied Studies. 1995.
Landry, M. Alcoholics Anonymous: Review of the Research. Rockville, MD: Substance Abuse and Mental Health Services Administration Office of Applied Studies, in press.
Leshner, A.I. Addiction is a brain disease and it matters. Science. 1997;278(3):45.
Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. National Institute on Drug Abuse Research Monograph, Number 86. Pub. No. (ADM) 88-1578. Rockville, MD: National Institute on Drug Abuse. 1988.
Lipton, D.S. The Effectiveness of Treatment for Drug Abusers Under Criminal Justice Supervision. Washington, DC: U.S. Department of Justice. 1995.
Lipton, D.S.; Maroles, E.; and Goldsmith, D.S. Pathways Into Treatment: A Study of the Drug Treatment Entry Process. New York: Narcotic and Drug Research, Inc. 1989.
Longshore, D.; Hsieh, S.; and Anglin, M.D. Reducing HIV risk behavior among injection drug users: Effect of methadone maintenance treatment on number of sex partners. International Journal of the Addictions. 1994;29(6):741-757. [pmid: 8034383].
Longshore, D.; Hsieh, S.; Danila, B.; and Anglin, M.D. Methadone maintenance and needle/syringe sharing. International Journal of the Addictions. 1993;28(10):983-996. [pmid: 8407026].
MacKenzie, D.L. Boot camp prisons: Components, evaluations, and empirical issues. Federal Probation. 1990;54:44-52.
MacKenzie, D.L. Boot camp prisons in 1993. National Institute of Justice Journal. 1993a:pp. 21-28.
MacKenzie, D.L. Multi-site Evaluation of Shock Incarceration: Executive Summary. Report to the National Institute of Justice. Washington, DC: U.S. General Accounting Office. 1993b.
MacKenzie, D.L., and Piquero, A. The impact of shock incarceration programs on prison overcrowding. Crime and Delinquency. 1994;40:222-249.
Mackenzie, D.L.; Shaw, J.W.; and Gowdy, C. An Evaluation of Shock Incarceration in Louisiana: Special Report. Washington, DC: National Institute of Justice. 1993.
Maddux, J.F., and McDonald, L.K. Status of 100 San Antonio addicts one year after admission to methadone maintenance. Drug Forum. 1973;2:239-252.
Martin, S.S.; Butzin, C.A.; and Inciardi, J.A. Assessment of a multistage therapeutic community for drug-involved offenders. Journal of Psychoactive Drugs. 1995;27(1):109-116. [pmid: 7602434].
McLellan, A.T.; Woody, G.E.; Luborsky, L.; and O'Brien, C.P. Is treatment for substance abuse effective?. Journal of the American Medical Association. 1982;247:1423-1428.
McLellan, A.T.; Woody, G.E.; Metzger, D.; McKay, J.; Durrell, J.; Alterman, A.I.; and O'Brien, C.P. Evaluating the effectiveness of addiction treatments: Reasonable expectations, appropriate comparisons. Milbank Quarterly. 1996;74(1):51-85. [pmid: 8596524].
Miller, B.A.; Downs, W.R.; and Testa, M. Interrelationships between victimization experiences and women's alcohol use. Journal of Studies on Alcohol. 1993;11(Suppl):109-117.
Morrisey, J. Shifting Boundaries, Reducing Costs: Managed Behavioural Health Care and the Criminal Justice System. New York: National GAINS Center for People with Co-Occurring Disorders in the Justice System. 1996.
National Center on Addiction and Substance Abuse at Columbia University (CASA). Behind Bars: Substance Abuse and America's Prison Population. New York: CASA. 1998.
National Commission on Correctional Health Care (NCCHC). "Position Statement: Women's Health Care in Correctional Settings." Adopted by the Board of Directors, September 1994.
National Commission on Correctional Health Care (NCCHC). "Position Statement: Continuity of Care." Adopted by the Board of Directors, November1995.
National GAINS Center. Just the Facts. Delmar, NY: National GAINS Center. 1997.
National Institute of Justice. 1990 Drug Use Forecasting: Annual Report on Adult and Juvenile Arrestees. Washington, DC: National Institute of Justice. 1991.
National Institute of Justice. 1996 Drug Use Forecasting: Annual Report on Adult and Juvenile Arrestees. Washington, DC: National Institute of Justice. 1997.
National Task Force on Correctional Substance Abuse Strategies. Intervening with Substance-Abusing Offenders: A Framework for Action. Washington, DC: U.S. Department of Justice. 1991.
Nielsen, A.L.; Scarpitti, F.R.; and Inciardi, J.A. Integrating the therapeutic community and work release for drug-involved offenders. The CREST program. Journal of Substance Abuse Treatment. 1996;13(4):349-358. [pmid: 9076653].
Ohio Department of Alcohol and Drug Addiction Services and Ohio Department of Rehabilitation and Correction. Ohio Plan for the Treatment of Alcohol and Other Drug-Impacted Offenders Under the Supervision of the Ohio Department of Rehabilitation and Correction. Columbus, OH: Department of Alcohol and Drug Addiction Services. 1997.
Parent, D. Boot camps failing to achieve goals. Overcrowded Times. 1993;4(4):1-15.
Peters, R.H., and Hills, H.A. Inmates with co-occurring substance abuse and mental health disorders. In: Steadman, H.J., and Cocozza, J.J., eds. Providing Services for Offenders with Mental Illness and Related Disorders in Prisons. Washington, DC: The National Coalition for the Mentally Ill in the Criminal Justice System, 1993.
Peters, R.H.; Kearns, W.D.; Marrin, M.R.; Dolente, A.S.; and May, R.L. Examining the effectiveness of in-jail substance abuse treatment. Journal of Offender Rehabilitation. 1993;19(3):1-39.
Peters, R.H.; May, R.L.; and Kearns, W.D. Drug treatment in jails: Results of a nationwide survey. Journal of Criminal Justice. 1992;20(4): 283-295.
Petersilia, J.; Turners, S.; and Deschences, E. The costs and effects of intensive supervision for drug offenders. Federal Probation. 1992;56(4):12-17.
Peyton, E. A Coordinated Approach to Managing the Drug Involved Offender. Wilmington, DE: Delaware Sentencing Accountability Commission. 1994.
Posluszny, M.P., Carry, K.L., and Kraska, S.L. Effectively Communicating With Offenders With Handicaps (ECOH) Trainer's Manuals. Buffalo, NY: Research Foundation of the State University of New York at Buffalo. 1996.
Powers, K.I., and Anglin, M.D. Cumulative versus stabilizing effects of methadone maintenance. Evaluation Review. 1993;17(3):243-270.
Rawson, R.A.; Obert, J.L.; and McCann, M.J. "The treatment of cocaine addiction and alcoholism at Sierra Tucson: Treatment outcome issues." Unpublished manuscript, 1990.
Reuter, P. Hawks Ascendant: The Punitive Trend of American Drug Policy. Santa Monica, CA: RAND Corp. 1992.
Sells, S.B., and Simpson, D.W. The Effectiveness of Drug Abuse Treatment. Vol. 3, Further Studies of Drug Users, Treatment, and Assessment of Outcomes During Treatment in the DARP. Cambridge, MA: Ballinger Publishing. 1976a.
Sells, S.B., and Simpson, D.W. The Effectiveness of Drug Abuse Treatment. Vol. 4, Evaluation of Treatment Outcomes for 1971-1972 DARP Admission Cohort. Cambridge, MA: Ballinger Publishing. 1976b.
Sells, S.B., and Simpson, D.W. The Effectiveness of Drug Abuse Treatment. Vol. 5, Evaluation of Treatment Outcomes for 1972-1973 DARP Admission Cohort. Cambridge, MA: Ballinger Publishing. 1976c.
Shwartz, M.; Baker, G.; Mulvey, K.; and Plough, A. Improving publicly funded abuse treatment: The value of case management. American Journal of Public Health. 1997;87:1659-1664.
Simpson, D.D. Treatment for drug abuse: Followup outcomes and length of time spent. Archives of General Psychiatry. 1981;38:875-889.
Simpson, D.D. National treatment system evaluation based on the Drug Abuse Reporting Program (DARP) follow-up research. In: Tims, F.M., and Ludford, J.P., eds. Drug Abuse Treatment Evaluation: Strategies, Process, and Prospects. National Institute on Drug Abuse Research Monograph, Number 51. NTIS Pub. No. 85-150365/AS. Rockville, MD: National Institute on Drug Abuse, 1984. pp. 29-41.
Simpson, D.D.; Joe, G.W.; Lehman, W.E.K.; and Sells, S.B. Addiction careers: Etiology, treatment, and 12-year follow-up outcomes. Journal of Drug Issues. 1986;16(1):107-121.
Simpson, D.D.; Joe, G.W.; Rowan-Szal, G.; and Greener, J. Client engagement and change during drug abuse treatment. Journal of Substance Abuse. 1995;7(1):117-134. [pmid: 7655308].
Simpson, D.D., and Sells, S.B., eds. Opioid Addiction and Treatment: A 12-Year Followup. Malabar, FL: Krieger Publishing. 1990.
Steadman, H.J. Boundary spanners: A key component for the effective interactions of the justice and mental health systems. Law and Human Behavior. 1992;16(1):75-87.
Stein, L.I. and Test, M.A. Alternative to mental hospital treatment: I. Conceptual model, treatment program, and clinical evaluation. Archives of General Psychiatry. 1980;37(4):392-397. [pmid: 7362425].
Swartz, J.A.; Lurigo, A.J.; and Slomka, S.A. The impact of IMPACT: An assessment of the effectiveness of a jail-based treatment program. Crime and Delinquency. 1996;42(4):553-573.
Taxman, F.S., and Spinner, D.L. The Jail Addictive Services (JAS) Project in Montgomery County, Maryland: Overview of Results from a 24 Month Follow-Up Study. College Park, MD: University of Maryland. 1996.
Taxman, F.S., and Spinner, D.L. "Jail Addiction Services (JAS) Demonstration Project in Montgomery County, Maryland: Jail and Community Based Substance Abuse Treatment Program Model." Final Report, March 1997.
Truman, B., and Brown, J.S. "HIV infection among intravenous drug users (IVDU) in NYC." Fifth International Conference on AIDS, Montreal, June 1989.
Tunis, S.L. Outcome evaluation of jail-based drug treatment: Effects on recidivism. NCCD Focus. 1995.
U.S. Census Bureau. "Resident Population of the United States: Estimates, by Sex, Race, and Hispanic Origin, With Median Age." http://www.census.gov [Accessed June 2, 1998].
University of California at Los Angeles Drug Abuse Research Center and the Office of Substance Abuse Programs of the California Department of Corrections. "A Descriptive Study of Parolee Outcomes in Eight Community Treatment Facilities." December 1995.
Virginia Addiction Technology Transfer Center. Criminal Justice-Substance Abuse Cross Training: Working Together for Change. Richmond, VA: Virginia Commonwealth University. 1996.
Walker, R.D.; Donovan, D.M.; Kivlahan, D.R.; and O'Leary, M.R. Length of stay, neuropsychological performance, and aftercare: Influences on alcohol treatment outcome. Journal of Consulting and Clinical Psychology. 1983;51:900-911.
Walsh, D.C.; Hingson, R.W.; Merrigan, D.M.; Levenson, S.M.; Cupples, L.A.; Heeren, T.; Coffman, G.A.; Becker, C.A.; Barker, T.A.; Hamilton, S.K.; McGuire, T.G.; and Kelly, C.A. A randomized trial of treatment options for alcohol-abusing workers. New England Journal of Medicine. 1991;325:775-782.
Weinman, B. A coordinated approach for drug-abusing offenders: TASC and parole. In: Leukefeld, C.G., and Tims, F.M., eds. Drug Abuse Treatment in Prisons and Jails. National Institute on Drug Abuse Research Monograph Number 118. NTIS Pub. No. 93-102143/LL(A14). Rockville, MD: National Institute on Drug Abuse, 1992. pp. 232-245.
Wexler, H.K. "The Amity prison TC evaluation: Inmate profiles and reincarceration outcomes." Presentation for the California Department of Corrections, 1996.
Wexler, H.K.; Falkin, G.P.; and Lipton, D.S. "A model prison rehabilitation program: An Evaluation of the Stay'N Out therapeutic community." A final report to the National Institute on Drug Abuse, August 31, 1988. New York: Narcotic and Drug Research, Inc.
Wexler, H.K.; Falkin, G.P.; and Lipton, D.S. Outcome evaluation of a prison therapeutic community for substance abuse treatment. Criminal Justice and Behavior. 1990;17(1):71-92.
Wexler, H.K.; Falkin, G.P.; Lipton, D.S.; and Rosenblum, A.B. Outcome evaluation of a prison therapeutic community for substance abuse treatment. In: Leukefeld, C.G., and Tims, F.M., eds. Drug Abuse Treatment in Prisons and Jails. National Institute on Drug Abuse Research Monograph, Number 118. NTIS Pub. No. 93-102143/LL(A14). Rockville, MD: National Institute on Drug Abuse, 1992. pp. 156-175.
Wexler, H.K., and Graham, W.F. "Prison-based therapeutic community for substance abusers: Follow-up outcomes." Paper presented at the American Psychological Association meeting, Los Angeles, October 1994.
Young, D.D. The Importance of the Coercive Aspects of Drug Offender Treatment. New York, NY: Vera Institute of Justice, 1995.