# Consensus Panel

Chair
- Dennis Moore, Ed.D.
- Director
- Rehabilitation Research and Training Center on Drugs and Disability
- Wright State University
- Dayton, Ohio
- John J. Benshoff, Ph.D., C.R.C.
- Associate Professor
- Rehabilitation Institute
- Southern Illinois University at Carbondale
- Carbondale, Illinois
- John D. Corrigan, Ph.D.
- Professor
- Division of Rehabilitation Psychology
- Department of Physical Medicine and Rehabilitation
- Ohio State University
- Columbus, Ohio
- Jo Ann Ford
- Assistant Director
- School of Medicine
- Substance Abuse Resources and Disabilities Issues
- Wright State University
- Dayton, Ohio
- Harry Kressler
- Executive Director
- Pima Prevention Partnership
- Tucson, Arizona
- Kathy A. Sandberg
- Program Manager
- Minneapolis Chemical Dependency Program for Deaf and Hard of Hearing Individuals
- Fairview University Medical Center
- Minneapolis, Minnesota
- Cecilia Anne Belone
- Social Worker
- Gallup, New Mexico
- Roslyn Pollack Corasaniti, R.N., M.S., C.R.R.N.
- Rehabilitation Training and Development Specialist
- James Lawrence Kernan Hospital
- Baltimore, Maryland
- John de Miranda, Ed.M.
- Executive Director
- National Association on Alcohol, Drugs, and Disability, Inc.
- San Mateo, California
- Marvis A. Doster, R.N., C.A.R.N.
- Addiction Education Coordinator
- Heartview Foundation
- Bismarck, North Dakota
- Nancy Ferreyra
- Executive Director
- Pacific Research and Training Alliance
- Oakland, California
- Brian Garrett, M.S.S.W.
- Brian Garrett Associates
- Nashville, Tennessee
- Jacqueline Hendrickson, M.S.W.
- Director
- Beltsville Counseling and Consultation
- Beltsville, Maryland
- Michael Nelipovich, Rh.D.
- Director
- Office for the Blind
- Division of Supportive Living
- Wisconsin Department of Health and Family Services
- Madison, Wisconsin
- Kenneth W. Perez, M.S.
- Addictions Program Specialist
- Bureau of Treatment Policy and Resource Development
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York