# Appendix F—Field Reviewers

- Charles H. Bombardier, Ph.D.
- Assistant Professor
- Department of Rehabilitation Medicine
- University of Washington School of Medicine
- Seattle, Washington

- Janet E. Dickinson, Ph.D.
- Marie H. Katzenbach School for the Deaf
- Trenton, New Jersey

- Janice M. Dyehouse, Ph.D., R.N.
- College of Nursing and Health
- University of Cincinnati
- Cincinnati, Ohio

- Roman Frankel
- Alcohol and Substance Abuse
- New Start, Inc.
- West Bloomfield, Michigan

- Jean F. Golden, R.N., M.L.I.R.
- Executive Director
- National Association on Alcohol, Drugs, and Disability
- Capital Area Center for Independent Living
- Lansing, Michigan

- Debra S. Guthmann, Ed.D.
- Director
- Pupil Personnel Services
- California School for the Deaf
- Fremont, California

- J.R. Harding
- Florida State University
- Tallahassee, Florida

- Karen Kelly-Woodall, M.S., M.A.C., N.C.A.C.I.I.
- Criminal Justice Coordinator
- Cork Institute
- Georgia Addiction Technology Transfer Center
- Morehouse School of Medicine
- Atlanta, Georgia

- Shane Koch
- Director
- Rehabilitation Doctors
- Abraxas of Ohio
- Shelby, Ohio

- Kathleen B. Masis, M.D.
- Medical Officer for Chemical Dependency
- Office for Healthcare Policy
- Billings Area Indian Health Service
- Public Health Service
- Department of Health and Human Services
- Billings, Montana

- Linda Mazie, M.Ed.
- Consultant
- Alcohol and Drug Abuse Coordinator
- Massachusetts Department of Public Health
- Dedham, Massachusetts

- Lisa Mojer-Torres, J.D.
- Consumer Representative Advocate
- Jersey City, New Jersey

- Jeffrey Nichols, M.D.
- Chief
- Geriatric Medicine
- Cabrini Center for Nursing and Rehabilitation
- New York, New York

- Anne H. Skinstad, Psy.D.
- Substance Abuse Counseling Program
- Addiction Technology Training Center
- University of Iowa
- Iowa City, Iowa

- Susan Storti, R.N., M.A., C.D.N.S.
- Co-Director
- Addiction Technology Transfer Center-New England
- Brown University
- Providence, Rhode Island

- Richard T. Suchinsky, M.D.
- Associate Director, Addictive Disorders
- Department of Veterans Affairs
- Mental Health and Behavioral Sciences Services
- Washington, D.C.

- Elizabeth Villalobos, M.S.W.
- Alcohol and Substance Abuse Coordinator
- Sunmount Developmental Disabilities Services Office
- Plattsburgh, New York

- Robert Walker, M.S.W., L.C.S.W., B.C.D.
- Director
- Bluegrass East Comprehensive Care Center
- Lexington, Kentucky

- Hazel Weiss
- Chair
- Disability Constituant Committee
- Hayward, California

- Eileen Wolkstein, Ph.D.
- Research Scientist
- Rehabilitation Counseling Program
- Department of Health Studies
- School of Education
- New York University
- New York, New York

- D. William Wood, M.P.H, Ph.D.
- Professor
- School of Public Health
- University of Hawaii
- Honolulu, Hawaii