# Appendix E—Resource Panel

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- George Kanuck
- Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Peter Mazzella, Jr., M.S.W.
- Program Officer
- Division of Associated Dental and Public Health Professions
- Health Resources and Services Administration
- Department of Health and Human Services
- Rockville, Maryland

- Mary Kay Mullen
- Health Insurance Specialist
- Medicaid Bureau
- Health Care Financial Administration
- Baltimore, Maryland

- Linda Peltz
- Health Insurance Specialist
- Medicaid Bureau
- Office of Long Term Care Services
- Health Care Financing Administration
- Baltimore, Maryland

- Hyden Shen
- Legislative Affairs
- Center for Substance Abuse Prevention
- Rockville, Maryland