# Appendix B—Information Resources

## Substance Use Disorder Resources for Persons With Disabilities

### The Minnesota Chemical Dependency Program for Deaf and Hard of Hearing Individuals

2450 Riverside Avenue Minneapolis, MN 55454 800-282-DEAF (3323) (voice/TTD) 612-672-4516(fax) MnCDDeafHH@aol.com

This program provides inpatient and outpatient substance use disorder treatment services for persons who are deaf or hard of hearing. In addition, the program provides specially developed treatment and prevention materials including a manual of specialized treatment approaches. It provides training about the delivery of substance use disorder services to deaf and hard of hearing persons. The program also receives Federal grant money to provide training opportunities to individuals who work with vocational rehabilitation. The program has a free catalog of materials on substance use disorders that are accessible for individuals who are deaf and hard of hearing.

### National Association on Alcohol, Drugs and Disability

2165 Bunker Hill Drive San Mateo, CA 94402-3801 650-578-8047 (voice/TDD) 650-286-9205 (fax) http://www.naadd.org/

The NAADD is a membership organization dedicated to improving prevention and treatment services for people with disabilities. It operates a web site and publishes the newsletter The Report on Alcohol, Drugs and Disability.

### New Jersey Coalition on Disabilities and Addiction

c/o Substance Abuse Resources 1806 Highway 35 Oakhurst, NJ 07755 (732) 663-1800 (voice)

### National Rehabilitation Hospital

ADA Health Care Facility Access Project 102 Irving Street, NW Washington, DC 20010-2949 (202) 877-1000 (voice) (202) 877-1450 (TDD)

### Pacific Research and Training Alliance (PRTA)

Alcohol, Drugs and Disability Project Suite 401 440 Grand Avenue Oakland, CA 94610-5085 510-465-0547 (voice) 510-465-2888 (TDD) 510-465-0505 (fax)

The PRTA provides technical assistance to all publicly funded substance use disorder programs in California working on disabilities and accessibility. It is working on a statewide project to assist substance abuse prevention, treatment, and recovery service providers in meeting the needs of clients with disabilities. Under this project, the PRTA works with providers from both the disability field and the substance use field. It is also developing a model substance use disorder prevention program for female adolescents with learning or physical disabilities. In addition to the documents PRTA has developed, it has an extensive library of training curricula, articles, research documents, and videotapes. Materials are available to the public.

### Pima Prevention Partnership

People with Disabilities Project Suite 105 300 North Main Street Tucson, AZ 85701 (520) 623-8871 (voice) (520) 623-8841 (TDD) (520) 623-8817 (fax)

### Rehabilitation Research and Training Center on Drugs and Disability (RRTC)

Wright State University School of Medicine P.O. Box 927 Dayton, Ohio 45401-0927 (513) 259-1384

The RRTC conducts research that focuses on the relationship between substance use disorders and the vocational success of individuals with disabilities. It conducts epidemiological studies, evaluates model systems, and provides training and technical assistance. It is funded by the National Institute of Disability and Rehabilitation Research (NIDRR), the Office of Special Education and Rehabilitative Services (OSERS), and the Department of Education.

### SARDI Project: Substance Abuse Resources and Disability Issues

SARDI Wright State University School of Medicine P.O. Box 927 Dayton, OH 45401 (937) 259-1384 (voice/TTD) (937) 259-1395 (fax)

The SARDI project provides direct, disability-specific substance use disorder and disability prevention, intervention, and treatment services. SARDI conducts educational training with agency staff to enhance knowledge and awareness of substance use and disability issues. SARDI can provide several resource materials, or refer people to other existing materials. Some of SARDI's resources are listed above in references.

SARDI is also the home of the federally funded Rehabilitation Research and Training Center (RRTC) on Drugs and Disability, funded by NIDRR.

## Federal ADA Enforcement Agencies

### Architectural and Transportation Barriers Compliance Board: The Access Board

Suite 1000 1331 F Street, NW Washington, DC 20004-1111 (800) USA-ABLE (voice) (800) 993-2822 (TTD) (202) 272-5434 (voice/TTD) (202) 272-5447 (fax) (202) 307-5448 (BBS) http://www.access-board.gov

An independent Federal agency that developed the ADA Accessibility Guidelines and other architectural accessibility guidelines for the Government, the Access Board enforces UFAS but not ADAAG standards. It provides technical assistance and information on the architectural requirements of the ADA and other access-related legislation, and architectural, communication, and transportation accessibility. The Access Board provides a list of free publications upon request.

### Equal Employment Opportunity Commission (EEOC)

1801 L Street, NW Washington, DC 20507 Complaints and Information (800) 669-4000 (voice) (800) 699-6820 (TTD)

Documents/Public Information Center (800) 669-3362 (voice) (800) 800-3302 (TTD) (513) 791-2954 (fax) (800) 669-4000 (referral to regional offices) http://www.eeoc.gov

EEOC is responsible for developing and enforcing the ADA employment regulations. It investigates charges of employment discrimination and works to resolve problems through conciliation. The 800 referral number also provides information on discrimination laws in English and Spanish. The EEOC provides free technical assistance publications on request.

### Department of Justice (DOJ)

Civil Rights Division Disability Rights Section P.O. Box 66738 Washington, DC 20035-6738 (800) 514-0301 (voice) (202) 514-0301 (voice) (800) 514-0383 (TTD) (202) 307-1198 (fax) (202) 514-6193 (BBS) http://www.usdoj.gov/crt/ada/adahom1.htm

Numbers listed are information lines on the ADA and the regulatory process.

The Equal Employment Opportunity Commission and the Department of Justice have jointly produced the Americans With Disabilities Act Handbook. This comprehensive publication provides background, summary, rulemaking history, overview of the regulations, section-by-section analysis of comments and revisions, P.L. 101-336, and annotated regulations of Titles I, II, and III. It includes appendices and related Federal disability laws. One copy is available free upon request from EEOC or DOJ or from the Disability and Business Technical Assistance Centers. Multiple copies can be purchased from:

U.S. Government Printing Office Superintendent of Documents Mail Stop: SSOP Washington, DC 20402-9328 (202) 783-3238 (voice) (202) 512-1426 (TDD)

### Department of Transportation

400 Seventh Street, SW Washington, DC 20590 Federal Highway Administration: (202) 366-3764 http://www.dot.gov Federal Transit Administration:

Documents and Questions (888) 446-4511 (voice) (202) 366-1656 (voice) (800) 877-8339 (TTD) (202) 366-7951 (fax)

Legal Questions (202) 366-4011 (voice) (202) 366-3809 (fax)

Complaints and Enforcement (202) 365-2285 (voice) (202) 366-0153 (TTD)

The Department of Transportation developed and continues to enforce the regulations to implement the transportation requirements of the ADA. It provides, upon request, information on the Title II and Title III requirements for public and specified private transportation, and publishes the Paratransit Handbook.

### Federal Communications Commission (FCC)

Office of Public Affairs Suite 1000 1919 M Street, NW Washington, DC 20554

Documents and Questions (202) 418-0190 (voice) (202) 418-2555 (TTD)

Legal Questions (202) 418-2357 (voice) (202) 418-0484 (TTD)

Complaints and Enforcement (202) 632-7553 (voice) (202) 418-0485 (TTD) http://www.fcc.gov

FCC developed and continues to enforce the regulations to implement the Title IV telecommunications requirements, such as those requiring relay services. It provides technical assistance and produces publications (available in print only).

## Federal and Federally Funded ADA Technical Assistance Agencies

### Administration of Developmental Disabilities

370 L'Enfant Promenade, SW Washington, DC 20447 (202) 690-6590

### Clearinghouse on Disability Information

OSERS/U.S. Department of Education Room 3132, Switzer Building 330 C Street, SW Washington, DC 20202 (202) 205-5465 (voice) (202) 732-1252 (fax)

### Job Accommodation Network (JAN)

West Virginia University P.O. Box 6080 Morgantown, WV 26506-6080 ADA Information (800) ADA-WORK (voice/TDD)

Accommodation Information (800) 526-7234 (voice/TDD) (304) 293-5407 (fax) (800) DIAL-JAN (Computer Bulletin Board System) janweb@icdi.wvu.edu http://janweb.icdi.wvu.edu/

A service of the President's Committee on Employment of People with Disabilities, JAN is an international, free consulting service that can provide information about job accommodation for people with disabilities. It helps solve specific job accommodation problems through its toll-free hotline.

### Library of Congress National Library Service for the Blind and Physically Handicapped

1291 Taylor Street, NW Washington, DC 20542 (800) 424-9100 http://www.loc.gov/nls

### MRI/Penn Research and Training Center on Vocational Rehabilitation And Mental Illness

Matrix Research Institute University of Pennsylvania Department of Psychiatry 6008 Wayne Avenue Philadelphia, PA 19144 (215) 438-8200 http://www.matrixresearch.com/

### National Institute on Disability and Rehabilitation Research

U.S. Department of Education Room 3060 330 C Street, SW Washington, D.C. 20202 (202) 205-8134 http://www.ed.gov/offices/OSERS/NIDRR

### National Institute on Neurological Disorders and Stroke

Building 31, Room 8A06 31 Center Drive, MSC 2540 Bethesda, MD 20892-2540 (301) 496-5751 (voice) (800) 325-9424 (voice) (301) 402-2186 (fax) http://www.nih.gov.ninds

### National Research and Training Center on Psychiatric Disability

University of IllinoisBChicago Suite 900 104 South Michigan Avenue Chicago, IL 60603-5901 (312) 422-8180 http://www.psych.uic.edu/~rtc/

### President's Committee on Employment of People With Disabilities

3rd floor 1331 F Street, NW Washington, DC 20004-1107 (202) 376-6200 (voice) (202) 376-6205 (TDD) (202) 376-6219 (fax) http://www.pcepd.gov

The President's Committee on Employment of People with Disabilities is a nationwide organization of 600 volunteer members that works to build and maintain a climate of acceptance of people with disabilities in the work force. It can assist in locating State governors' committees and local mayoral committees that address disability issues. It produces technical assistance materials, including videotapes, public service announcements, and fact sheets, and provides information on job accommodation, assistive technology, tax incentives, and other topics. A list of publications can be obtained by calling the above numbers.

### Rehabilitation Research and Training Center for Persons Who Are Deaf or Hard of Hearing

University of Arkansas 4601 West Markham Street Little Rock, AR 72205 (501) 686-9691 http://www.uark.edu/depts/rehabres/

### Rehabilitation Research and Training Center on Blindness and Low Vision

Mississippi State University P.O. Drawer 6189 Mississippi State, MS 39762 (601) 325-2001 http://www.msstate.edu/dept/rrtc/blind.html

### Rehabilitation Services Administration

U.S. Department of Education Switzer Building 330 C Street, SW Washington, D.C. 20202-2500 (202) 205-5482 http://www.ed.gov/officers/OSERS/RSA/rsa.html

### Research and Training Center on Rehabilitation for Persons With Long-Term Mental Illness

Boston University/Sargent College Center for Psychiatric Rehabilitation 930 Commonwealth Avenue Boston, MA 02215 (617) 353-3549 http://web.bu.edu/SARPSYCH/

### Research and Training Center on Community Integration of Individuals With Traumatic Brain Injury

Mount Sinai School of Medicine One Gustave L. Levy Place, Box 1240 New York, NY 10029-6574 (212) 241-7917 http://academic.mssm.edu/tbinet/

### Research and Training Center on Community Living

University of Minnesota College of Education and Human Development Institute on Community Integration RTC on Residential Services and Community Living 150 Pillsbury Drive, SE Minneapolis, MN 55455 (612) 624-5005 http://www.ici.coled.umn.edu/ici/rtc/

### Research and Training Center on Improving Community-Based Rehabilitation Programs

University of WisconsinBStout College of Human Development Stout Vocational Rehabilitation Institute Menomonie, WI 54751 (715) 232-1219 http://www.chd.uwstout.edu/svri/rtc.htm1

### Research and Training Center on Improving the Functioning of Families Who Have Members With Disabilities

University of Kansas Beach Center on Families and Disability 3111 Haworth Hall Lawrence, KS 66045 (913) 864-7600 http://www.lsi.ukans.edu/beach/beachhp.htm

### Research and Training Center on Independent Living for Underserved Populations

University of Kansas 4089 Dole Building Lawrence, KS 66045 (913) 864-0575 http://www.lsi.ukans.edu/rtcil/rtcbroc.htm

### Research and Training Center on Rural Rehabilitation Services

University of Montana Rural Institute on Disabilities 52 Corbin Hall Missoula, MT 59812 (406) 243-5467 http://ruralinstitute.umt.edu/

## Other General Disability Resources

### Access/Abilities

P.O. Box 458 Mill Valley, CA 94942 (415) 388-3250

### The Accreditation Council

Suite 406 100 West Road Towson, MD 21204-2331 (410) 583-0060 (410) 583-0063 (fax) http://www.thecouncil.org

This organization works to promote and measure quality services for people with disabilities and performs accreditation reviews for agencies that work with people with disabilities.

### American Association of People With Disabilities

Suite 330 1819 H Street, NW Washington, DC 20006 (800) 840-8844 (voice) (202) 457-0473 (fax) http://www.aapd.com

### American Association of Retired Persons Disability Initiative

601 E Street, NW Washington, DC 20049 (800) 424-3410 (voice) http://www.aarp.org

### American Medical Rehabilitation Providers Association (AMRPA)

3rd floor 1606 20th Street, NW Washington, DC 20009 (888) 346-4624 (202) 833-9168 (fax) http://amrpa.firminc.com

### Association on Higher Education and Disability

P.O. Box 21192 Columbus, OH 43221-0192 (614) 488-4972 (voice) (614) 488-1174 (fax) ahead@postbox.acs.ohio-state.edu http://www.ahead.org

This organization is comprised of most student disability offices in higher education. It can assist with identifying disability services at nearby community colleges and universities.

### Centers for Independent Living (CILs)

Centers for Independent Living is a national network of more than 200 community-based service and advocacy programs run by people with disabilities. If you are unable to find a Center for Independent Living in your phone book, contact any of the following for assistance in locating one near you:

- Your State vocational rehabilitation agency
- National Council on Independent Living

Suite 209 1916 Wilson Boulevard Arlington, VA 22201 (703) 525-3406 (voice) (703) 525-4153 (TDD) (703) 525-3409 (fax) ncil@tsbbsS02.tnet.com

- Independent Living Research Utilization Center

Suite 100 2323 South Shepherd Houston, TX 77019 (713) 520-0232 (voice) (713) 520-5136 (TDD) (713) 520-5785 (fax) http://www.bcm.tmc.edu/ilru

### Consortium for Citizens With Disabilities

Suite 1212 1730 K Street, NW Washington, DC 20006 (202) 785-3388 (voice) (202) 467-4179 (fax) http://www.radix.net/~ccd/

### Health Web

Internet Resource http:///www.ghsl.nwu.edu/healthweb/ Independent Living for the Handicapped 1301 Belmont Street, NW Washington, DC 20009 (202) 797-9803

### Mainstream, Inc

Suite 830 3 Bethesda Metro Center Bethesda, MD 20814 (301) 654-2400 (voice/TDD) (301) 654-2403 (fax) mainstream@aol.com

### National Alliance of the Disabled

1352 Sioux Street Orange Park, FL 32065 http://www.naotd.org

The NAOTD is an online informational and advocacy organization working toward equal rights for people with disabilities.

### National Association of Developmental Disabilities Councils

Suite 103 1234 Massachusetts Avenue, NW Washington, DC 20005 (202) 347-1234 (voice) (202) 347-4023 (fax) http://www.igc.apc.org/NADDC

### National Clearinghouse of Rehabilitation Training Materials

816 West 6th Street Oklahoma State University 5202 Richmond Hill Drive Stillwater, OK 74078-4080 (800) 223-5219 (voice) (405) 624-0695 (fax) http://www.nchrtm.okstate.edu

This organization is an excellent resource for training materials in disability areas.

### National Easter Seal Society

Suite 1800 230 West Monroe Street Chicago, IL 60606 (312) 726-6200 (voice) (312) 726-4258 (TDD) (312) 726-1494 (fax)

This organization provides technical assistance and referral to employers and individuals with disabilities on such topics as assistive technology, vocational training, and rehabilitation.

### National Information Center for Children and Youth With Disabilities

8th floor 1875 Connecticut Avenue, NW Washington, DC 20009 (202) 884-8200 (202) 884-8441 (fax) http://www.nichcy.org

### National Institute on Life Planning For Persons With Disabilities

Administrative Office P.O. Box 5093 Twin Falls, ID 833-5093 (208) 735-8556 (voice) (208) 735-8562 (fax) http://www.sonic.net/nilp

### National Organization on Disability

Suite 600 910 16th Street, NW Washington, DC 20006 (202) 293-5960 (202) 293-7999 (fax) http://www.nod.org

### National Rehabilitation Information Center

Suite 935 8455 Colesville Road Silver Spring, MD 20910 (800) 346-2742 (301) 495-5626 (TTD) (301) 587-1967 (fax) http://www.naric.com/naric/

### Rehabilitation Accreditation Commission

4891 East Grand Road Tucson, AZ 85712 (520) 325-1044 (voice/TDD) (520) 318-1129 (fax)

The Rehabilitation Accreditation Commission promotes quality services for people with disabilities by establishing and using standards of quality for such services.

### Rehabilitation Institute of Chicago

345 East Superior Street Chicago, IL 60611 (312) 908-6066 (voice) webmaster@rehabchicago.org http://www.rehabchicago.org

### Society for the Advancement of Travel for the Handicapped

Suite 610 347 Fifth Avenue New York, NY 10016 (212) 447-7284 sathtravel@aol.com

### World Institute on Disability

Suite 100 510 16th Street Oakland, CA 94612-1500 (510) 763-4100 (voice) (510) 208-9496 (TTD) (510) 763-4109 (fax) http://www.wid.org

## Disability-Specific Service Resources

### American Deafness and Rehabilitation Association (ADARA)

P.O. Box 6956 San Mateo, CA 94403 (650) 372-0620 (voice/TTD) (650) 372-0661 (fax) ADARAorg@aol.com

The ADARA is the largest national organization for professionals who work with persons who are deaf and hard of hearing. It provides information and referral, and networking and holds biennial conferences in topics related to substance use disorders, mental health, vocation rehabilitation, job coaching, education, and interpreting.

### American Foundation for the Blind

Suite 300 11 Penn Plaza New York, NY 10001 (800) 232-5463 (voice) (212) 620-2158 (TDD) (212) 727-7418 (fax) (800) 829-0500 (product information) http://www.afb.org/afb

This organization provides information and referral on adaptive and assistive technology for people who are blind or visually impaired.

### American Printing House for the Blind

1839 Frankfurt Avenue Louisville, KY 40206 (502) 895-2405 (voice) (502) 899-2274 (fax) (800) 223-1839 (Customer Service)

This organization provides Braille and large print books (including textbooks), computer voice synthesis hardware and software, computer-related materials on disk, and instructional aids.

### Association of Late Deafened Adults, Inc

Suite 274 10310 Main Street Fairfax, VA 22030 (404) 289-1596 (TTD) (404) 284-6862 (fax) http://www.alda.org

### The Arc (formerly Association for Retarded Citizens)

Suite 300 500 East Border Street Arlington, TX 76010 (817) 261-6003 (voice) (817) 277-0553 (TDD) (817) 277-3491 (fax) http://thearc.org/

The Arc aids the employment of people with mental retardation or developmental disability and publishes resource materials.

### Brain Injury Association

105 North Alfred Street Alexandria, VA 22314 (703) 236-6000 (voice) (703) 236-6001 (fax)

### Children and Adults With ADD

Suite 101 499 Northwest 10th Avenue Plantation, FL 33317 (800) 233-4050 (954) 587-4599 (fax)

### Learning Disabilities Association of America

4156 Library Road Pittsburgh, PA 15234-1349 (412) 341-1515 (412) 344-0224 (fax) http://www.ldanatl.org/

The Learning Disabilities Association of America is a national, nonprofit, volunteer organization dedicated to enhancing the quality of life for all people with learning disorders and their families. It is an advocacy organization that conducts education, research, and service.

### National Association of the Deaf

814 Thayer Avenue Silver Spring, MD 20910-4500 (301) 587-1788 (voice) (301) 587-1789 (TTD) (301) 587-1791 (fax) http://www.nad.org

The National Association of the Deaf provides information and referral on deafness and accommodations for people who are deaf. It has local chapters in each State.

### National Center for Learning Disabilities, Inc

Suite 1401 381 Park Avenue South New York, NY 10016 (212) 545-7510 (888) 575-7373 http://www.ncld.org/

### National Information Center on Deafness

Galludet University 800 Florida Avenue, NE Washington, DC 20002-3695 202-651-5051 (voice) 202-651-5054 (fax) http://www.galludet.edu/~nicd

### National Organization for Rare Disorders

P.O. Box 8923 New Fairfield, CT 06812-8923 (203) 246-6518 (voice) (800) 999-6673 (voice) (203) 746-6481 (fax) http://www.pcnet.com/~orphan

A disease is considered rare if it affects fewer than 200,000 people in the United States; over 5,000 different disorders fall into this category. The NORD provides information and referrals for people with these lesser known diseases.

### National Spinal Cord Injury Hotline

Kernan Hospital 2200 Kernan Drive Baltimore, MD 21207 (800) 526-3456

### Paralyzed Veterans of America

801 18th Street, NW Washington, D.C. 20006 (202) 872-1300 http://www.pva.org/

### Rehabilitation Research and Training Center on Severe Traumatic Brain Injury

1314 West Main Street Richmond, VA 23284-2011 (804) 828-1851 (voice)

### Stroke Clubs International

805 12th Street Galveston, TX 77550 (409) 762-1022

### Substance and Alcohol Intervention Services for the Deaf (SAISD)

Rochester Institute of Technology National Technical Institute for the Deaf 115 Lomb Memorial Drive Rochester, NY 14623-5608 (716) 475-4978 (voice/TDD) http://www.rit.edu/sa/coun/saisd

This center publishes the National Directory of Prevention and Treatment Programs Accessible to the Deaf, a comprehensive directory of substance use disorder programs for people who are deaf. The 1998 edition is available electronically on SAISD's website. Printed copies of the 1995 directory can be obtained through the Rochester Institute of Technology's bookstore at (716) 475-2501.

### The University of California Center On Deafness (UCCD)

Suite 10 3333 California Street San Francisco, CA 94143-1208 (415) 476-4980 (voice) (415) 476-7600 (TDD)

The UCCD is a research and training center focusing on deafness and mental health. They have a variety of materials, including training videos for substance use disorder treatment providers entitled "Meeting the Challenge: Working with Deaf People in Recovery," and "I Can: Stories of Deaf and Hard of Hearing People in Recovery."