# Appendix A -- Bibliography

Alterman, A., and Tarter, R. An examination of selected typologies: Hyperactivity, familial, and antisocial alcoholism. In: Galanter, M., ed. Recent Developments in Alcoholism. New York: Plenum Press. 1986:pp. 169-189.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 1994.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance Related Disorders, 2nd ed. Chevy Chase, MD: American Society of Addiction Medicine. 1996.
Anthenelli, R.M., and Schuckit, M.A. Genetics. In: Lowinson, J.H.; Ruiz, P.; and Millman, R.B., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 39-50.
Ashery, R.S. Case management community advocacy for substance abuse clients. In: Ashery, R.S., ed. Progress and Issues in Case Management. National Institute on Drug Abuse Research Monograph, Number 127. DHHS Pub. No. ADM 92-1946. Rockville, MD: National Institute on Drug Abuse. 1992:pp. 383-394.
Ballew, J.R., and Mink, G. Case Management in Social Work: Developing the Professional Skills Needed for Work With Multiproblem Clients. Springfield, IL: Charles C. Thomas. 1996.
Barco, P.; Crosson, B.; Bolesta, M., Werts, D.; and Stout, R. Training awareness and compensation in postacute rehabilitation. In: Kreutzer, J.S., and Wehman, P.H., eds. Cognitive Rehabilitation for Persons With Traumatic Brain Injury: A Functional Approach. Baltimore: P.H. Brookes. 1991:pp. 129-146.
Betts, H.B., and Richmond, J.B. Disability in America Report. 1991.
Blackwell, L.R. Going beyond the anger. In: Garretson, M.D., ed. Deafness 1993-2013: A Deaf American Monograph. Vol. 43. Silver Spring, MD: National Association of the Deaf. 1993:pp. 11-14.
Brown, V.B.; Ridgely, M.S.; Pepper, B.; Levine, I.S.; and Ryzlewicz, H. The dual crisis: Mental illness and substance abuse: Present and future directions. American Psychologist. 1989;44(3):565-569. [pmid: 2648909].
Bruckman, B.; Bruckner, V.T.; and Calabrese, C. Alcohol and Drug Programs and the Americans With Disabilities Act: A Compliance Guide for Privately-Operated Programs. Oakland, CA: Pacific Research and Training Alliance. 1997.
Burgdorf, R.L. Equal access to public accommodations. In: West, J., ed. The Americans With Disabilities Act. New York: Milbank Memorial Fund. 1991:pp. 183-213.
Buss, A., and Cramer, C. Incidence of Alcohol Use by People With Disabilities: A Wisconsin Survey of People With Disability. Madison, WI: Office of Persons with Disabilities. 1989.
Cahalan, D.; Cisin, I.H.; and Crossley, H.M. American Drinking Practices: A National Study of Drinking Behavior and Attitudes. New Haven, CT: College University Press. 1969.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse. 1994.
Center for Substance Abuse Treatment. Substance Abuse Among Older Adults. 1998.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. 1998.
Corrigan, J.D. Substance abuse as a mediating factor in outcome from traumatic brain injury. Archives of Physical Medicine and Rehabilitation. 1995;76:302-309.
Corrigan, J.D.; Rust, E.; and Lamb-Hart, G.L. The nature and extent of substance abuse problems in persons with traumatic brain injury. Journal of Head Trauma Rehabilitation. 1995;10(3):29-46.
DeLoach, C., and Greer, B.G. Adjustment to Severe Physical Disability: A Metamorphosis. New York: McGraw Hill. 1981.
de Miranda, J., and Cherry, L. California responds: Changing treatment systems through advocacy for the disabled. Alcohol, Health and Research World. 1989;13(2):154-157.
de Miranda, J.; Kiley, D.; and Gambina, H. Inform Yourself: Alcohol, Drugs, and Spinal Cord Injury. A Resource Guide for Persons With Spinal Cord Injury and Their Families. San Mateo, CA: Novation. 1992.
Dick, J.E. "Signing for a high: A study of alcohol and drug use by deaf and hard of hearing adolescents." Ph.D. dissertation, Rutgers University, New Brunswick. 1996.
Drake, R.E.; Mueser, K.T.; Clark, R.E.; and Wallach, M.A. The course, treatment, and outcome of substance disorder in persons with severe mental illness. American Journal of Orthopsychiatry. 1996;66(1): 42-51.
Drubach, D.A.; Kelly, M.P.; Winslow, M.M.; and Flynn, J.P.G. Substance abuse as a factor in the causality, severity, and recurrence of traumatic brain injury. Maryland Medical Journal. 1993;42(10): 989-993.
Elmquist, D.L.; Morgan, D.P.; and Bolds, P.K. Alcohol and other drug use among adolescents with disabilities. International Journal of the Addictions. 1992;27(12):1475-1483. [pmid: 1452397].
Ford, J.A., and Moore, D. Substance Abuse Resources and Disability Issues Training Manual. 1992.
Freeman, A.C.; Ferreyra, N.; and Calabrese, C. Fostering Recovery for Women with Disabilities: Eliminating Barriers to Substance Abuse Programs. Meeting the Needs of Women with Disabilities: A Blueprint for Change. Oakland, CA: Berkeley Planning Associates. 1997.
Frieden, A. L. Substance abuse and disability: The role of the independent living center. Journal of Applied Rehabilitation Counseling. 1990;21(3):33-36.
Galanter, M., and Kleber, H. Textbook of Substance Abuse Treatment. 1994.
Glover, N.; Janikowski, T.P.; and Benshoff, J.J. The incidence of incest histories among clients receiving substance abuse treatment. Journal of Counseling and Development. 1995;73:475-480.
Greenwood, W. Alcoholism: A complicating factor in the rehabilitation of disabled individuals. Journal of Rehabilitation. 1984;50(4):51-52, 72.
Greer, B.G. Substance abuse among people with disabilities: A problem of too much accessibility. Journal of Rehabilitation. 1986;14(1):34-37.
Guthmann, D. "An analysis of variables that impact treatment outcomes of chemically dependent deaf and hard of hearing individuals." Ph.D. dissertation, University of Minnesota, Minneapolis. 1996.
Guthmann, D.; Lybarger, R.; and Sandberg, K. Chemical dependency treatment: Specialized approaches for deaf and hard of hearing clients. In: Proceedings from the Innovative Partnerships in Recovery: The Diverse Deaf Experience. Washington, DC: Gallaudet University. 1994:pp. 31-50.
Hanson, V.L., and Padden, C.A. Interactive video for bilingual ASL/English instruction of deaf. American Annals of the Deaf. 1989;July:209-213.
Heinemann, A.; Doll, M.; Armstrong, K.; and Schnoll, S. Substance use and receipt of treatment by persons with long-term spinal cord injuries. Archives of Physical Medicine and Rehabilitation. 1991;72:482-487.
Heinemann, A.W.; Doll, M.; and Schnoll, S. Treatment of alcohol abuse in persons with recent spinal cord injuries. Alcohol Health and Research World. 1989;13(2):110-117.
Heinemann, A.W.; Keen, M.; Donohue, R.; and Schnoll, S. Alcohol use by persons with recent spinal cord injury. Archives of Physical Medicine and Rehabilitation. 1988;69:619-624.
Helwig, A.A., and Holicky, R. Substance abuse in persons with disabilities: Treatment considerations. Journal of Counseling and Development. 1994;72(2),:227-33.
Hser, Y.; Anglin, M.D.; and Chou, C. Evaluation of drug abuse treatment: A repeated measures design assessing methadone maintenance. Evaluation Review. 1988;12(5):547-71.
Jessor, R., and Jessor, S. Problem Behavior and Psychological Development: A Longitudinal Study of Youth. New York: Academic Press. 1977.
Kelley, S.D.M., and Benshoff, J.J. Dual diagnosis of mental illness and substance abuse: Contemporary challenges for rehabilitation. Journal of Applied Rehabilitation Counseling. 1997;28(3):43-9.
Kessler, D.T., and Klein, M.A. Drug use patterns and risk factors of adolescents with physical disabilities. International Journal of the Addictions. 1995;30:1243-1270.
Kirkubakaran Kirubakaran, V.; Kumar, N.; Powell, B.; Tyler, A.; and Armatas, P. Survey of alcohol and drug misuse in spinal cord injured veterans. Journal of Studies in Alcohol. 1986;47(3):223-27.
Kosten, T.R.; Rounsaville, B.J.; and Kleber, H.D. Concurrent validity of the Addiction Severity Index. Journal of Nervous and Mental Disease. 1983;171(10):606-610. [pmid: 6619823].
Kressler, H., and Ward, E. Bridging cultures: Providers work with disability services. Alcoholism and Drug Abuse Weekly. 1997;August 4:3.
Kreutzer, J.S.; Witol, A.D.; and Marwitz, J.H. Alcohol and drug use among young persons with traumatic brain injury. Journal of Learning Disabilities. 1996;29(6):64-51.
Kubler-Ross, E. On Death and Dying. 1969.
Ladd, P. Deaf cultural studies--towards an end to internal strife. In: Garretson, M.D., ed. Viewpoints on Deafness: A Deaf American Monograph. Vol. 42. Silver Spring, MD: National Association of the Deaf. 1992:pp. 83-87.
LaDue, R.A.;. Streissguth, A.P.; Randals, S.P. Clinical considerations pertaining to adolescents and adults with FAS. In: Sorderegger, T.B., ed. Perinatal Substance Abuse: Research Findings and Clinical Implications. Baltimore: The Johns Hopkins University Press. 1992:pp. 104-131.
Langley, M.J.; Lindsay, W.P.; Lam, C.S.; and Priddy, D.A. A comprehensive alcohol abuse treatment programme for persons with traumatic brain injury. Brain Injury. 1990;4(1):77-86. [pmid: 2404532].
LaPlante, M.P. How Many Americans Have a Disability. 1992.
LaPlante, M.P.; Kennedy, J.; Kaye, S.; and Wenger, B.L. Disability and Employment. 1997.
Li, L., and Moore, D. Acceptance of disability and its correlates. Journal of Social Psychology. 1998;138(10):1-25.
Livneh, H., and Male, R. Functional limitations: A review of their characteristics and vocational impact. Journal of Rehabilitation. 1993;59(4):44-50.
Manisses Communication Group. California pact on disabled could open floodgates. Alcoholism and Drug Abuse Weekly. 1994;October 17:1-7.
Marshak, L., and Seligman, M. Counseling Persons With Physical Disabilities: Theoretical And Clinical Perspectives. Austin, TX: Pro-Ed. 1993.
Minnesota Chemical Dependency Treatment Program for Deaf and Hard of Hearing Individuals. Clinical Approaches: A Model for Treating Chemically Dependent Deaf and Hard of Hearing Individuals. Minneapolis, MN: Deaconess Press. 1996.
Moore, D. "Research in substance abuse and disabilities: the implications for prevention and treatment. " Plenary Session Paper Presented at the Third National Prevention and Training Conference: People with Disabilities. Phoenix, AZ, April 4-7. 1990.
Moore, D. "Substance abuse prevention and intervention for students with physical disabilities." Paper presented at the National Conference for the Association on Handicapped Students Service Programs in Post-Secondary Education. Nashville, TN, August 1-4. 1990.
Moore, D. "The magnitude of the problem: the scope of prevention and treatment issues for persons with mental retardation or learning disability." Paper presented at Alcohol and Other Drug Abuse: Implications for Mental Retardation and Learning Disability Conference. Hofstra University, Hempstead, NY, June 10. 1991.
Moore, D. "Middle-aged and older adults with disabilities." Paper presented at the Fourth National Prevention Research and Training Conference. Salt Lake City, UT, March 22. 1991.
Moore, D. "Substance Abuse and persons with disabilities: A significant public health problem." Paper presented at the American Public Health Association. Westin Peachtree Plaza Hotel, Atlanta, GA, November 13. 1991.
Moore, D. Substance abuse assessment and diagnosis in medical rehabilitation. NeuroRehabilitation. 1992;2(1):7-15.
Moore, D., and Ford, J.A. Prevention of substance abuse among persons with disabilities: A demonstration model. Prevention Forum. 1991;11(2):1-3, 7-10.
Moore, D.; Greer, B.; and Li, L. Alcohol and other substance use/abuse among people with disabilities. Journal of Social Behavior and Personality. 1994;2(5):369-382.
Moore, D., and Li, L. Substance use among rehabilitation consumers for vocational rehabilitation services. Journal of Rehabilitation. 1994;38(2):124-133.
Moore, D., and Li, L. Final Report to NIDRR: Results of an Epidemiologic Survey of Drug Use Among Persons with Disabilities. Dayton, OH: Rehabilitation Research and Training Center on Drugs and Disability. 1996.
Moore, D., and Polsgrove, L. Disabilities, developmental handicaps, and substance misuse: A review. International Journal of the Addictions. 1991;26(1):65-90. [pmid: 1829719].
Moore, D., and Siegal, H. Double trouble: Alcohol and other drug use among orthopedically impaired college students. Alcohol Health and Research World. 1989;13(2):118-123.
Motet-Grigoras, C., and Schuckit, M. Depression and substance abuse in handicapped young men. Journal of Clinical Psychiatry. 1986;47:234-237.
National Association on Alcohol, Drugs and Disability. Facts Sheet on Alcohol, Drugs, and Disability. 1997.
Nelipovich, M., and Buss, E. Alcohol abuse in persons who are blind. Alcohol Health and Research World. 1989;13(2):128-131.
Office for Alcohol and Substance Abuse Services, New York State. "Management sytems data." Internal report. Albany, NY. 1998.
Ohio Valley Center for Brain Injury Prevention. "Suggestions for Providers Working With Persons With Brain Injury." Training sheet. Columbus, OH. 1998.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.; Judd, L.; and Goodwin, F. Comorbidity of mental disorders with alcohol and other drugs abuse: Results from the epidemiologic catchment area (ECA) study. Journal of the American Medical Association. 1990;264(19):2511-2518. [pmid: 2232018].
Rehabilitation Research and Training Center on Drugs and Disability. National Needs Assessment Survey Results Summary. 1995.
Rehabilitation Research and Training Center on Drugs and Disability. Substance Abuse, Disability and Vocational Rehabilitation. 1996.
Research and Training Center on Independent Living. Guidelines for Reporting and Writing About People with Disabilities. 1996.
Research Development Associates. "Comprehensive treatment for critical populations: A model substance abuse treatment program for racial and ethnic minority group members with disabilities." Evaluation summary. Dayton, OH. 1997.
Rhodes, S.S., and Jasinski, D.R. Learning disabilities in alcohol dependent adults: A preliminary study. Journal of Learning Disabilities. 1990;23:551-556.
Robert Wood Johnson Foundation. The Robert Wood Johnson Foundation Annual Report 1994: Cost Containment. Princeton, NJ: Robert Wood Johnson Foundation. 1994.
Rourke, S.B., and Loberg, T. The neurobehavioral correlates of alcoholism. In: Grant I., and Adams, K.M., eds. Neuropsychological Assessment Of Neuropsychiatric Disorders, 2nd ed. New York: Oxford University Press. 1996:pp. 423-485.
Schaschl, S., and Straw, D. Results of a model intervention program for physically impaired persons. Alcohol and Research World. 1989;13:150-153.
Schaschl, S., and Straw, D. Chemical dependency: The avoided issue for physically disabled persons. Aid Bulletin. 1990;11(2):1-8.
Schwab, A.J., and DiNitto, D.M. Factors related to the successful vocational rehabilitation of substance abusers. Journal of Applied Rehabilitation Counseling. 1993;24(3):11-20.
Schwab, A.J., Smith, T.W., and DiNitto, D. Client satisfaction and quality vocational rehabilitation. Journal of Rehabilitation. 1993;59(4):17-23.
Shrey, D.F. Disability management. In: Dell Orto, A.E., and Marinelli, R.P., eds. Encyclopedia of Disability and Rehabilitation. New York: Macmillan Publishing. 1995:pp. 270-274.
Soderstrom, C.A.; Smith, G.S.; Dischinger, P.C.; McDuff, D.R.; Hebel, J.R.; Gorelick, D.A.; Kerns, T.J.; Ho, S.M.; and Read, K.M. Psychoactive substance use disorders among seriously injured trauma center patients. Journal of the American Medical Association. 1997;277(22):1769-1774. [pmid: 9178789].
Sparadeo, F.R., and Gill, D. Effects of prior alcohol use on head injury recovery. Journal of Head Trauma Rehabilitation. 1989;4(1):75-82.
Stedman, T.L. Stedman's Medical Dictionary. 1990.
Storti, S. Alcohol, Disabilities, and Rehabilitation. 1997.
Substance Abuse Resources and Disability Issues. Blindness, Visual Impairments and Substance Abuse: Facts for Substance Abuse Prevention and Treatment Professionals. Dayton, OH: Substance Abuse Resources and Disability Issues. 1995.
Susser, E.S.; Lin, S.P.; and Conover, S.A. Risk factors for homelessness among patients admitted to a state mental hospital. American Journal of Psychiatry. 1991;148:1659-1664.
Taylor, H.; Kagay, M.R.; and Leichenko, S. The ICD Survey of Disabled Americans: Bringing Disabled Americans Into the Mainstream. New York: Louis Harris and Associates, Inc. 1986.
Varley, C.K. Schizophreniform psychoses in mentally retarded adolescent girls following sexual assault. American Journal of Psychiatry. 1984;141(4):593-595. [pmid: 6703145].
Vash, C. Psychology of Disability. New York: Springer Publishing. 1981.
Wallace, B.C. Crack cocaine smokers as adult children of alcoholics: The dysfunctional family link. Journal of Substance Abuse Treatment. 1990;7:89-100.
World Health Organization. International Classification of Impairments, Disabilities, and Handicaps: A Manual of Classification Relating to the Consequences of Disease. Geneva: World Health Organization. 1980.
World Health Organization. Guidelines for Counseling About HIV Infection and Disease. WHO AIDS Series 8. Geneva: World Health Organization. 1990.