# Foreword

The Treatment Improvement Protocol (TIP) series fulfills SAMHSA/ CSAT's mission to improve treatment of substance use disorders by providing best practices guidance to clinicians, program administrators, and payers. TIPs are the result of careful consideration of all relevant clinical and health services research findings, demonstration experience, and implementation requirements. A panel of non-Federal clinical researchers, clinicians, program administrators, and patient advocates debates and discusses their particular area of expertise until they reach a consensus on best practices. This panel's work is then reviewed and critiqued by field reviewers.

The talent, dedication, and hard work that TIPs panelists and reviewers bring to this highly participatory process have bridged the gap between the promise of research and the needs of practicing clinicians and administrators. We are grateful to all who have joined with us to contribute to advances in the substance abuse treatment field.

- Nelba Chavez, Ph.D.
- Administrator
- Substance Abuse and Mental Health Services Administration
- Camille T. Barry, Ph.D., R.N.
- Acting Director
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration