# Consensus Panel

## Chair

- Stephanie O'Malley, Ph.D.
- Associate Professor
- Department of Psychiatry
- Yale University
- New Haven, Connecticut

## Workgroup Leaders

- Raymond Anton, M.D.
- Professor of Psychiatry
- Institute of Psychiatry
- Medical University of South Carolina
- Charleston, South Carolina

- Mary Elizabeth McCaul, Ph.D.
- Associate Professor
- Department of Psychiatry and Behavioral Sciences
- School of Medicine
- Johns Hopkins University
- Baltimore, Maryland

- Patrice Muchowski, Sc.D.
- Vice President
- Clinical Services
- Adcare Hospital of Worcester
- Worcester, Massachusetts

- Robert Swift, M.D., Ph.D.
- Psychiatrist-In-Chief
- Department of Psychiatry
- Roger Williams Medical Center
- Providence, Rhode Island

## Panelists

- Lisa M. D'Angelo, R.N., M.S.N., A.R.N.P.
- Chief Executive Officer
- Administration
- SMARxT Consultants
- Wilmington, Delaware

- Ray Daw
- Executive Director
- Robert Wood Johnson Foundation
- Northwest New Mexico Fighting Back, Inc.
- Nanizhoozhi Center, Inc.
- Gallup, New Mexico

- Joseph Gallina, Pharm.D.
- Director
- Pharmacy Services
- University of Maryland Medical System
- Baltimore, Maryland

- Hans C. Geisse, M.D.
- Chief
- Chemical Dependency and Recovery Program
- Southern California Permanente Medical Group
- Moreno Valley, California

- Robert S. Geissinger
- Counselor
- Division of Alcoholism and Substance Abuse
- Washington State Department of Social and Health Services
- Lacey, Washington

- Sarz Maxwell, M.D.
- Program Coordinator
- Center for Addictive Problems
- Chicago, Illinois

- David W. Oslin, M.D.
- Assistant Professor
- Addiction and Geriatric Psychiatry
- Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania

## Special Consultants

- Charles P. O'Brien, M.D., Ph.D.
- Professor and Director
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Robert Rosenheck, M.D.
- Director
- Division of Mental Health Services and Treatment Outcome Research
- School of Medicine
- Yale University
- New Haven, Connecticut

- Joseph Volpicelli, M.D., Ph.D.
- Associate Professor
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania