# Chapter 1 --The Current Situation

Some 9.6 percent of men and 3.2 percent of women in the United States will become alcohol dependent at some time in their lives (Grant, 1992). The most recent National Household Survey on Drug Abuse estimates that about 32 million Americans had engaged in binge or heavy drinking (five or more drinks on the same occasion at least once in the previous month) and that about 11 million Americans were heavy drinkers (five or more drinks on the same occasion on at least five different days in the past month) (Substance Abuse and Mental Health Services Administration [SAMHSA], Office of Applied Studies, 1996). Alcohol-related disorders occur in up to 26 percent of general medical clinic patients, a prevalence rate similar to those for other chronic diseases such as hypertension and diabetes (Fleming and Barry, 1992). Alcoholics consume more than 15 percent of the national health care budget (Rice et al., 1990), seeking attention in medical settings for various secondary health problems (Schurman et al., 1985).

Researchers calculate that about 18 million Americans with alcohol abuse problems need treatment, but only one-fourth of them receive it (Institute for Health Policy, 1993; Institute of Medicine, 1996). People suffering from alcohol disorders include teenagers, women, men, the employed or the unemployed, alone and isolated or part of a family, homeless or financially secure, and people of every race, creed, and level of education. People who have mental illness have a higher rate of substance abuse and alcoholism than everyone else; they also have a harder time getting help and staying in treatment. Recent tests on the medication naltrexone indicate that this drug can help many of those people. Naltrexone has been proven to decrease problem drinking--in some cases by almost half--when used with existing treatments, compared with other treatments used alone (O'Malley et al., 1992; Volpicelli et al., 1992, 1997).

## The Evolution of Treatment

Today, alcoholism treatment generally consists of medical, psychological, and social interventions to reduce or eliminate the harmful effects of alcohol dependence and abuse on the individual, his or her family and associates, and others in society. Treatment approaches range from lower cost, less intensive methods (e.g., brief interventions/advice to stop or reduce drinking, referral to self-help programs) to higher cost, more intensive methods (e.g., inpatient detoxification and rehabilitation programs, residential treatment).

Many different orientations toward treatment, such as 12-Step, behavioral, motivational, medical, and spiritual, are used to various extents by treatment programs. A patient may need a different type of treatment at different stages in his or her life and in different phases of his or her addiction. There is no perfect way to treat every person, but research is under way to determine how to choose and apply the most appropriate treatment specifically to the particular needs of each patient.

Although the stigma attached to alcohol problems has abated, many still believe that alcohol problems represent a moral failing and that an alcoholic should be able to "white-knuckle" his or her way to sobriety. Such biases can be held by the patients themselves, by treatment providers with different backgrounds, by insurers, by communities, and by the legal establishment regionally. Those biases about the best way to treat substance abuse and dependence sometimes prevent patients from receiving adequate and appropriate care.

Understanding that the abuse of alcohol and other substances causes profound changes in brain chemistry and function may help to reduce the stigma and shame surrounding repeated relapse to alcohol abuse. Continued education and understanding should reduce the bias against the use of medications to treat the illness of substance abuse and dependence. As scientists continue mapping the brain, particularly those areas that govern pleasure and addiction, pharmacotherapies such as naltrexone will likely be used more often.

## Development and Current Use of Naltrexone

Naltrexone was initially developed for the treatment of narcotic or opioid addiction, including heroin, morphine, and oxycodone (e.g., Percocet). Naltrexone is an opioid antagonist, which means that it blocks the effects of opioids. During the 1980s, animal studies revealed that opioid antagonists, including naltrexone, which the FDA approved in 1984 for treating opiate addiction, also decreased alcohol consumption by blocking certain opioid receptors (i.e., action sites) in the brain that help to maintain drinking behavior. Building on those laboratory findings, researchers conducted human clinical trials to determine whether naltrexone could play a role in the treatment of alcoholism (O'Malley et al., 1992; Volpicelli et al., 1992). The results of these studies suggest that naltrexone, when combined with appropriate psychosocial therapy, can effectively reduce craving and relapse rates in general populations of alcohol-dependent patients (Volpicelli, 1995). Based on such findings, the FDA approved naltrexone for use in the treatment of alcoholism.

Psychosocial treatments for alcoholism have been shown to increase abstinence rates and improve the quality of life for many alcoholics (Miller and Hester, 1986). Nonetheless, a significant proportion of alcoholics find it difficult to maintain initial treatment gains and eventually relapse to problematic drinking. When used as an adjunct to psychosocial therapies for alcohol-dependent or alcohol-abusing patients, naltrexone can reduce

- The percentage of days spent drinking
- The amount of alcohol consumed on a drinking occasion
- Relapse to excessive and destructive drinking

The National Institute on Alcohol Abuse and Alcoholism is currently funding over a dozen clinical trials with naltrexone, and a large-scale multisite study of naltrexone in combination with 12-Step facilitation therapy is being funded through the Department of Veterans Affairs.

## Overview

The Consensus Panel that developed this TIP includes the country's leading experts on naltrexone. The Panel's aim is to provide counselors, treatment providers, clinicians, and the general public with a responsible, understandable assessment of the current data on the effectiveness and use of naltrexone for the treatment of alcoholism and alcohol abuse. Members of the Panel have drawn on the published literature, study findings that have been presented at conferences, and on their considerable clinical experience.

Chapter 2 is a "how to" chapter that covers the important clinical issues in using naltrexone as an adjunct to treatment. These issues include a review of eligibility considerations for naltrexone treatment, the initiation of treatment, ongoing treatment, and treatment termination issues. Chapter 3 details the basic neurobiological and preclinical research supporting clinical investigations of naltrexone for treatment of alcohol dependence. An overview of neurological reinforcement systems and drug dependence explains how naltrexone works. Chapter 4 describes the specific findings of the initial two clinical trials (O'Malley et al., 1992; Volpicelli et al., 1992) that established the efficacy of naltrexone in the treatment of alcohol dependence. It also describes subsequent research to identify the patients most likely to benefit from naltrexone treatment, the differential subjective effects of naltrexone, the use of naltrexone for other patient populations, naltrexone in the context of other pharmacotherapies, and directions for future research. Chapter 5 provides a brief overview of naltrexone as a medication, including its development and clinical role, its mechanism of action, its pharmacokinetic properties, its safety and common adverse effects, and some clinical considerations when prescribing this medication.

The bibliography for this TIP appears in Appendix A. Appendix B guides clinicians or administrators who are interested in adding naltrexone to the formulary of their health care organization. Included in this appendix is an extensive list of Federal and private World Wide Web sites for readers who may want to access additional information about substance abuse treatment through the Internet. Appendix C details the process by which innovations are adopted over time and outlines strategies that encourage technology transfer and research utilization. For the organization that would like to incorporate naltrexone as a potential treatment adjunct, this appendix offers suggestions on how to prepare the system for this change. Appendix D provides two instruments to help treatment providers: The Obsessive Compulsive Drinking Scale and the Alcohol Urge Questionnaire.

It is important to remember that naltrexone may not be effective for every person with alcohol abuse disorder. In combination with other therapies, however, it can greatly improve outcomes for certain individuals. This TIP will help providers use naltrexone safely and effectively to enhance patient care and improve treatment outcomes.