# Appendix F --Field Reviewers

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Deborah Duran, Ph.D.
- Research and Policy
- National Coalition of Hispanic Health
- Washington, D.C.

- John E. Emmel, M.D.
- Medical Director
- Department of Alcohol and Other Drug Abuse Services
- Mount Pleasant, South Carolina

- Arthur C. Evans, Ph.D.
- Director
- Managed Care
- Connecticut Department of Mental Health and Adolescent Services
- Hartford, Connecticut

- Michael Fingerhood, M.D.
- Associate Professor of Medicine
- Department of Chemical Dependence
- School of Medicine
- Johns Hopkins University
- Baltimore, Maryland

- Mark S. Gold, Ph.D.
- Professor
- Department of Neurosciences, Psychiatry, Community Health, and Family Medicine
- University of Florida Brain Institute
- Gainesville, Florida

- Gil Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- George Kanuck
- Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Raye Z. Litten, Ph.D.
- Program Officer
- Treatment Research Branch
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Kensington, Maryland

- Charles P. O'Brien, M.D., Ph.D.
- Professor and Director
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Patricia Reihl
- Coordinator
- Spring House
- Paramus, New Jersey

- Terry K. Schultz, M.D.
- Colonel/Chief
- Alcohol and Drug Addiction Services
- Consultant to the Army Surgeon General
- United States Army Medical Corps
- Falls Church, Virginia

- Richard B. Seymour
- Director
- Information and Education
- Haight Ashbury Free Clinics, Inc.
- San Francisco, California

- David E. Smith, M.D.
- Medical Director
- Haight Ashbury Free Clinics, Inc.
- San Francisco, California

- Christopher J. Stock, Pharm.D.
- Clinical Pharmacist
- Substance Abuse Program
- Veterans Medical Center
- Salt Lake City, Utah

- Richard T. Suchinsky, M.D.
- Associate Chief
- Addictive Disorders
- Department of Veterans Affairs
- Mental Health and Behavioral Sciences Services
- Washington, D.C.

- Roy L. Sykes, M.A.C., C.D.S. III
- Services Supervisor
- Therapeutic Health Services
- Seattle, Washington

- Joseph Volpicelli, M.D., Ph.D.
- Associate Professor
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania