# Appendix E --Resource Panel

- Lonn Aussicker
- Public Health Analyst
- HIV Linkage Branch
- Division of Clinical Programs
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Johanna Clevenger, M.D.
- Chief
- Alcoholism and Substance Abuse Program Branch
- Indian Health Service
- Rockville, Maryland

- Jerry Cott, Ph.D.
- Head
- Pharmacologic Treatment Program
- National Institute of Mental Health
- Rockville, Maryland

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Gil Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Lt. Col. Kenneth J. Hoffman, M.D., M.P.H., M.C.F.S.
- Director, Center for Addiction Medicine
- Center for Training and Education in Addiction Medicine (C-Team)
- Department of Preventive Medicine/Biometrics
- Uniformed Services University of the Health Sciences
- Bethesda, Maryland

- Jeffrey T. Kramer
- Executive Vice President
- National Treatment Consortium
- Washington, D.C.

- Raye Z. Litten, Ph.D.
- Program Officer
- Treatment Research Branch
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Kensington, Maryland

- Patrice Muchowski, Sc.D.
- Vice President
- Clinical Services
- Adcare Hospital of Worcester
- Worcester, Massachusetts

- Eleanor Sargent
- Director
- Clinical Issues
- The National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Terry K. Schultz, M.D.
- Colonel/Chief
- Alcohol and Drug Addiction Services
- Consultant to the Army Surgeon General
- United States Army Medical Corps
- Falls Church, Virginia