# Appendix D --Instruments

This appendix includes

- Alcohol Urge Questionnaire
- Obsessive Compulsive Drinking Scale

## Alcohol Urge Questionnaire

Listed below are questions that ask about your feelings about drinking. The words "drinking" and "have a drink" refer to having a drink containing alcohol, such as beer, wine, or liquor. Please indicate how much you agree or disagree with each of the following statements by placing a single mark (like this: X ) along each line between STRONGLY DISAGREE and STRONGLY AGREE. The closer you place your mark to one end or the other indicates the strength of your disagreement or agreement. Please complete every item. We are interested in how you are thinking or feeling right now as you are filling out the questionnaire.

RIGHT NOW

1. All I want to do now is have a drink. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
2. I do not need to have a drink now. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
3. It would be difficult to turn down a drink this minute. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
4. Having a drink now would make things seem just perfect. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
5. I want a drink so bad I can almost taste it. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
6. Nothing would be better than having a drink right now. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
7. If I had the chance to have a drink, I don't think I would drink it. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE
8. I crave a drink right now. STRONGLY DISAGREE:______:______:______:______:______:______:______:STRONGLY AGREE

Reprinted with permission from Michael J. Bohn.

## Obsessive Compulsive Drinking Scale

Directions: The questions below ask you about your drinking alcohol and your attempts to control your drinking. Please circle the number next to the statement that best applies to you.

1. How much of your time when you're not drinking is occupied by ideas, thoughts, impulses, or images related to drinking?
  0 )None
  1 )Less than 1 hour a day
  2 )1-3 hours a day
  3 )4-8 hours a day
  4 )Greater than 8 hours a day
2. How frequently do these thoughts occur?
  0 )Never
  1 ) No more than 8 times a day
  2 )More than 8 times a day, but most hours of the day are free of those thoughts
  3 )More than 8 times a day and during most hours of the day
  4 )Thoughts are too numerous to count, and an hour rarely passes without several such thoughts occurring.

Insert the Higher Score of Questions 1 or 2 here _____

3 How much do these ideas, thoughts, impulses, or images related to drinking interfere with your social or work (or role) functioning? Is there anything you don't or can't do because of them? [If you are not currently working, how much of your performance would be affected if you were working?]
  0 )Thoughts of drinking never interfere--I can function normally.
  1 )Thoughts of drinking slightly interfere with my social or occupational activities, but my overall performance is not impaired.
  2 )Thoughts of drinking definitely interfere with my social or occupational performance, but I can still manage.
  3 )Thoughts of drinking cause substantial impairment in my social or occupational performance.
  4 )Thoughts of drinking interfere completely with my social or work performance.
4 How much distress or disturbance do these ideas, thoughts, impulses, or images related to drinking cause you when you're not drinking?
  0 )None
  1 )Mild, infrequent, and not too disturbing
  2 )Moderate, frequent, and disturbing, but still manageable
  3 )Severe, very frequent, and very disturbing
  4 )Extreme, nearly constant, and disabling distress
5 How much of an effort do you make to resist these thoughts or try to disregard or turn your attention away from these thoughts as they enter your mind when you're not drinking? (Rate your efforts made to resist these thoughts, not your success or failure in actually controlling them.)
  0 )My thoughts are so minimal, I don't need to actively resist. If I have thoughts, I make an effort to always resist.
  1 )I try to resist most of the time.
  2 )I make some effort to resist.
  3 )I give in to all such thoughts without attempting to control them, but I do so with some reluctance.
  4 )I completely and willingly give in to all such thoughts.
6 How successful are you in stopping or diverting these thoughts when you're not drinking?
  0 )I am completely successful in stopping or diverting such thoughts.
  1 )I am usually able to stop or divert such thoughts with some effort and concentration.
  2 )I am sometimes able to stop or divert such thoughts.
  3 )I am rarely successful in stopping such thoughts and can only divert such thoughts with difficulty.
  4 )I am rarely able to divert such thoughts even momentarily.
7 How many drinks do you drink each day?
  0 )None
  1 )Less than 1 drink per day
  2 )1-2 drinks per day
  3 )3-7 drinks per day
  4 )8 or more drinks per day
8 How many days each week do you drink?
  1. )None
  2. )No more than 1 day per week
  3. )2-3 days per week
  4. )4-5 days per week
  5. )6-7 days per week

Insert the Higher Score of Questions 7 or 8 here____

9 How much does your drinking interfere with your work functioning? Is there anything that you don't or can't do because of your drinking? [If you are not currently working, how much of your performance would be affected if you were working?]
  0 )Drinking never interferes--I can function normally.
  1 )Drinking slightly interferes with my occupational activities, but my overall performance is not impaired.
  2 )Drinking definitely interferes with my occupational performance, but I can still manage.
  3 )Drinking causes substantial impairment in my occupational performance.
  4 )Drinking problems interfere completely with my work performance.
10 How much does your drinking interfere with your social functioning? Is there anything that you don't or can't do because of your drinking?
  0 ) Drinking never interferes--I can function normally.
  1 )Drinking slightly interferes with my social activities, but my overall performance is not impaired.
  2 )Drinking definitely interferes with my social performance, but I can still manage.
  3 )Drinking causes substantial impairment in my social performance.
  4 )Drinking problems interfere completely with my social performance.

Insert the Higher Score of Questions 9 or 10 here____

11 If you were prevented from drinking alcohol when you desired a drink, how anxious or upset would you become?
  0 )I would not experience any anxiety or irritation.
  1 )I would become only slightly anxious or irritated.
  2 )The anxiety or irritation would mount, but remain manageable.
  3 )I would experience a prominent and very disturbing increase in anxiety or irritation.
  4 )I would experience incapacitating anxiety or irritation.
12 How much of an effort do you make to resist consumption of alcoholic beverages? (Only rate your effort to resist, not your success or failure in actually controlling the drinking.)
  0 )My drinking is so minimal, I don't need to actively resist. If I drink, I make an effort to always resist.
  1 )I try to resist most of the time.
  2 )I make some effort to resist.
  3 )I give in to almost all drinking without attempting to control it, but I do so with some reluctance.
  4 )I completely and willingly give in to all drinking.
13 How strong is the drive to consume alcoholic beverages?
  0 )No drive
  1 )Some pressure to drink
  2 )Strong pressure to drink
  3 )Very strong drive to drink
  4 )The drive to drink is completely involuntary and overpowering.
14 How much control do you have over the drinking?
  0 )I have complete control.
  1 )I am usually able to exercise voluntary control over it.
  2 )I can control it only with difficulty.
  3 )I must drink and can only delay drinking with difficulty.
  4 )I am rarely able to delay drinking even momentarily.

Insert the Higher Score of Questions 13 or 14 here____