# Appendix A -- Bibliography

Addiction Research Foundation (ARF). Fast Fax Facts on Naltrexone. 1996.
Alcoholics Anonymous, 3rd ed. 1976.
Allan, A.M., and Harris, R.A. Acute and chronic ethanol treatments alter GABA receptor-operated chloride channels. Pharmacology, Biochemistry and Behavior. 1987;27:665-670.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 1987.
American Society of Addiction Medicine. 1996.
Annis, H.M., and Peachy Peachey, J.E. The use of calcium carbimide in relapse prevention counseling counselling: Results of a randomized controlled trial. British Journal of Addiction. 1992;87:63-72.
Anton, R.F. New directions in the pharmacotherapy of alcoholism. Psychiatric Annals. 1995;25:353-362.
Anton, R.F. 1997.
Anton, R.F.; Moak, D.H.; and Latham, P.K. The obsessive compulsive drinking scale: A new method of assessing outcome in alcoholism treatment studies. Archives of General Psychiatry. 1996;53(3):225-231. [pmid: 8611059].
Atkinson, R.L. Endocrine and metabolic effects of opiate antagonists. Journal of Clinical Psychiatry. 1984;45(9):20B24.
Bien, T.; Miller, W.; and Tonigan, J. Brief interventions for alcohol problems: A review. Addiction. 1993;88(3):315-335. [pmid: 8461850].
Bohn, M.J.; Krahn, D.D.; and Staehler, B.A. Development and initial validation of a measure of drinking urges in abstinent alcoholics. Alcohol Clinical and Experimental Research. 1995;19(3):600-606.
Bohn, M.J.; Kranzler, H.R.; Beazoglou, D.; and Staehler, B.A. Naltrexone and brief counseling to reduce heavy drinking. American Journal of the Addictions. 1994;3:91-99.
Bray, J.H., and Rogers, J.C. Linking psychologists and family physicians for collaborative practice. Professional Psychology: Research and Practice. 1995.
Carroll, K.; Ziedonis, D.; O'Malley, S.S.; McCance-Katz, E.; Gordon, L.; and Rounsaville, B. Pharmacologic interventions for alcohol- and cocaine-abusing individuals: A controlled study of disulfiram vs. naltrexone. American Journal on Addictions. 1993;2:77-79.
Center for Substance Abuse Treatment (CSAT). Detoxification from Alcohol and Other Drugs. 1995.
Center for Substance Abuse Treatment (CSAT). Substance Abuse Treatment and Domestic Violence. 1997.
Charness, M.E. Alcohol and the brain. Alcohol Health and Research World. 1990;14(2):85-89.
Charness, M.E.; Hu, G.; Edwards, R.H.; and Querimit, L.A. Ethanol increases delta-opioid receptor gene expression in neuronal cell lines. Molecular Pharmacology. 1993;44:1119-1127.
Charness, M.E.; Querimit, L.A.; and Diamond, I. Ethanol increases the expression of functional delta-opioid receptors in the neuroblastoma X glioma NG108-15 hybrid cells. Journal of Biologic Chemistry. 1986;261:3164-3169.
Cloninger, C.R. Recent advances in family studies of alcoholism. Progress in Clinical and Biological Research. 1987;241:47-60.
Cloninger, C.R. Etiologic factors in substance abuse: An adoption study perspective. In: Pickens, R.W., and Svikis, D.S., eds. Biological Vulnerability to Drug Abuse. NIDA Research Monograph Series, Number 89. Rockville, MD: National Institute on Drug Abuse. 1988:pp. 52-72.
Cornelius, J.R.; Salloum, I.M.; Ehler, J.G.; Jarrett, P.J.; Cornelius, M.D.; Perel, J.M.; Thase, M.E.; and Black, A. Fluoxetine in depressed alcoholics: A double-blind, placebo-controlled trial. Archives of General Psychiatry. 1997;54:700-705.
Croop, R.S., and Chick, J. American and European clinical trials of naltrexone. In: Litten, R.Z., and Fertig, J. (chairs), International Update: New Findings on Promising Medications. Alcoholism: Clinical and Experimental Research 20(8 suppl.):216A-218A. 1996.
Croop, R.S.; Faulkner, E.B.; and Labriola, D.F., for the Naltrexone Usage Study Group. The safety profile of naltrexone in the treatment of alcoholism: Results from a multicenter usage study. Archives of General Psychiatry. 1997;54(12):1130-1135. [pmid: 9400350].
Croop, R.S.; Labriola, D.F.; Wroblewski, J.M.; and Nibbelink, D.W. A Multicenter Safety Study of Naltrexone as Adjunctive Pharmacotherapy for Individuals with Alcoholism. 1995.
Davidson, D.; Swift, R.; and Fitz, E. Naltrexone increases the latency to drink alcohol in social drinkers. Alcoholism: Clinical and Experimental Research. 1996;20:732-739.
deWaele, J.P.; Papachristou, D.N.; and Gianoulakis, C. The alcohol-preferring C57-L/6 mice present an enhanced sensitivity of the hypothalmic b-endorphin system to ethanol than the alcohol-avoiding DBA/2 mice. Journal of Pharmacology and Experimental Therapeutics. 1992;281:788-794.
Di Chiara, G. Alcohol and dopamine. Alcohol Health and Research World. 1997;21(2):108-114. [pmid: 15704345].
Dillon, D., and Homer, A.L. Answers to frequently asked questions about naltrexone treatment for alcoholism. In: Rounsaville, B.J.; O'Malley, S.; and O'Conner, P., eds. Guidelines for the Use of Naltrexone in the Treatment of Alcoholism. New Haven, CT: APT Foundation. 1995.
Doty, P., and deWit, H. Effects of naltrexone pretreatment on the subjective and performance effects of ethanol in social drinkers. Behavioral Pharmacology. 1995;6:386-394.
Doyle, R. Deaths due to caused by alcohol Scientific American 1996http://www.health.org/pressrel/alcart.htm
DuPont Pharma. 1995.
Farren, C.K., and O'Malley, S. Sequential use of naltrexone in the treatment of relapsing alcoholism. American Journal of Psychiatry. 1997.
Fleming, M.F., and Barry, K.L. Clinical overview of alcohol and drug disorders. In: Fleming, M.F., and Barry, K.L., eds. Addictive Disorders. Chicago: Mosby Yearbook. 1992:pp. 3-21.
Froehlich, J.C. Genetic factors in alcohol self-administration. Journal of Clinical Psychiatry. 1995;56(suppl. 7):15-23.
Froehlich, J.C. The neurobiology of ethanol-opioid interactions in ethanol reinforcement Alcoholism: Clinical and Experimental Research 20:181A-186A 1996View this and related citations using
Froehlich, J.C. Opioid peptides. Alcohol Health and Research World. 1997;21(2):132-135. [pmid: 15704349].
Froehlich, J.C., and Li, T.-K. Opioid peptides. In: Galanter, M., ed. Recent Developments in Alcoholism: Volume 11. Ten Years of Progress. New York: Plenum Press. 1993:pp. 187-205.
Froehlich, J.C., and Wand, G. The neurobiology of ethanol-opioid interactions in ethanol reinforcement. Alcoholism: Clinical and Experimental Research. 1996;20(8)181A-186A.
Frye, G.D., and Breese, G.R. GABAergic modulation of ethanol-induced motor impairment. Journal of Pharmacology and Experimental Therapeutics. 1982;223:750-756.
Gamage, J.R., and Zerkin, E.L. Narcotic Antagonists. 1973.
Gianoulakis, C., and Angelogianni, P. Characterization of beta-endorphin peptides in the spinal cord of the rat. Peptides. 1989;10(5):1049-1054. [pmid: 2532738].
Gianoulakis, C.; Angelogianni, P.; Meany, M.; Thavundayil, J.; and Thawar, V. Endorphins in individuals with high and low risk for development of alcoholism. In: Reid, L.D., ed. Opioids, Bulimia, and Alcohol Abuse and Alcoholism. New York: Springer-Verlag. 1990:pp. 229-246.
Gianoulakis, C., and Barcomb, A. Effect of acute ethanol in vivo and in vitro on the beta-endorphin system in the rat. Life Sciences. 1987;40(1):19B28.
Gianoulakis, C.; Krishnan, B.; and Thavundayil, J. Enhanced sensitivity of pituitary beta-endorphin to ethanol in subjects at high risk of alcoholism. Archives of General Psychiatry. 1996;53:250-257.
Ginsburg, H.M. Naltrexone: Its Clinical Utility. 1984.
Goodwin, D.W.; Schulsinger, F.; Hermansen, L.; Guze, S.D.; and Winokur, G. Alcohol problems in adoptees raised apart from alcoholic biological parents. Archives of General Psychiatry. 1973;28:238-243.
Gonzales, R.A., and Jaworski, J.N. Alcohol and glutamate. Alcohol Health and Research World. 1997;21(2):120-126. [pmid: 15704347].
Gonzalez, J.P., and Brogden, R.N. Naltrexone: A review of its pharmacodynamic and pharmacokinetic properties and therapeutic efficacy in the management of opioid dependence. Drugs. 1988;35:192-213.
Gonzalez, N.M.; Campbell, M.; Small, A.M.; Shay, J.; Bluhm, L.D.; Adams, P.B.; and Foltz, R.L. Luteinizing hormone regulators: Luteinizing hormone releasing hormone analogs, estrogens, opiates, and estrogen-opiate hybrids. Psychopharmacology Bulletin. 1994;30(2):203-208. [pmid: 7831456].
Grant, B.F. DSM-II-R and proposed DSM-IV alcohol abuse and dependence, United States, 1988: A nosological comparison. Alcoholism: Clinical and Experimental Research. 1992;16(6):1068-1077.
Gritz, E.R.; Shiffman, S.M.; Jarvik, M.E.; Schlesinger, J.; and Charuvastra, V.C. Naltrexone: Physiological and psychological effects of single doses. Clinical Pharmacology and Therapeutics. 1976;19:773-776.
Hiller-Sturmhöfel, S. Signal transmission among nerve cells. Alcohol Health and Research World. 1995;19(2):128.
Ho, A.K.S.; Chen, R.C.A.; and Morrison, J.M. Interactions of narcotics, narcotic antagonists, and ethanol during acute, chronic, and withdrawal states. Annals of the New York Academy of Sciences. 1976;281:297-310.
Institute for Health Policy, Brandeis University. Substance Abuse: The Nation's Number One Health Problem: Key Indicators for Policy. 1993.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. 1996.
Jaffe, J.H. Cyclazocine in the treatment of narcotic addiction. Current Psychiatric Therapies. 1967;7:147-156.
Jaffe, A.J.; Rounsaville, B.; Chang, G.; Schottenfeld, R.S.; Meyer, R.E.; and O'Malley, S.S. Naltrexone, relapse prevention, and supportive therapy with alcoholics: An analysis of patient treatment matching. Journal of Consulting and Clinical Psychology. 1996;64:1044-1053.
Jenab, S., and Inturrisi, C.E. Ethanol and naloxone differentially upregulate delta opioid receptor gene expression in neuroblastoma hybrid (NG108-15) cells. Molecular Brain Research. 1994;27:95-102.
Judson, B.A.; Carney, T.M.; and Goldstein, A. Naltrexone treatment of heroin addiction: Efficacy and safety in a double-blind dosage comparison. Drug and Alcohol Dependence. 1981;7:325-346.
Julius, D., and Renault, P., eds. Narcotic Antagonists: Naltrexone Progress Report. 1976.
Keith, L.D.; Crabbe, J.C.; Robertson, L.M.; and Kendall, J.W. Ethanol stimulated endorphin and corticotropin in vitro. Brain Research. 1986;367(1-2):222-229.
King, A.C.; Volpicelli, J.R.; Frazer, A.; and O'Brien, C.P. Effect of naltrexone on subjective alcohol response in subjects at high and low risk for future alcohol dependence. Psychopharmacology. 1997;129:15-22.
Koob, G.F., and LeMoal, M. Drug abuse: Hedonic homeostatic dysregulation. Science. 1997;278(5335):52-58. [pmid: 9311926].
Koob, G.F.; Rassnick, S.; Heinrichs, S.; and Weiss, F. Alcohol: The reward system and dependence. In: Jansson, B.; Jörnvall, H.; Rydberg, U.; Terenius, L.; and Vallee, B.L., eds. Toward a Molecular Basis of Alcohol Use and Abuse, Boston: Birkhauser-Verlag. 1994:pp. 103-114.
Kranzler, H.R.; Burleson, J.A.; Korner, P.; Del Boca, F.K.; Bohn, M.J.; Brown, J.; and Liebowitz, N. Placebo-controlled trial of fluoxetine as an adjunct to relapse prevention in alcoholics. American Journal of Psychiatry. 1995;152:391-397.
Kranzler, H.R., and Meyer, R.E. An open trial of buspirone in alcoholics. Journal of Clinical Psychopharmacology. 1989;9(5):379-380. [pmid: 2677064].
Kranzler, H.R.; Tennen, H.; Penta, C.; and Bohn, M.J. Targeted naltrexone treatment of early problem drinkers. Addictive Behavior. 1997;22(3):431-436.
Kuhar, M.J. Basic Neurobiological Research: 1989-1991. 1991.
Le, A.D., and Sellers, E.M. Interaction between opiate and 5-HT3 receptor antagonists in the regulation of alcohol intake. Alcohol and Alcoholism. 1994;29(suppl. 2):545-549.
LeMarquand, D.; Pihl, R.O.; and Benkelfat, C. Serotonin and alcohol intake, abuse, and dependence: Clinical evidence. Biological Psychiatry. 1994;36(5):326-337. [pmid: 7993959].
Leshner, A.I. Addiction is a brain disease, and it matters. Science. 1997;278(5335):45-47. [pmid: 9311924].
Li, X.-W.; Li, T.-K.; and Froehlich, J.C. Alcohol alters preproenkephal in mRNA content in the shell and the core of the nucleus accumbens. Alcoholism: Clinical and Experimental Research. 1996;20:53A.
Liljequest, Liljequist S., and Engel, J. Effects of GABAergic agonists and antagonists on various ethanol-induced behavioral changes. Psychopharmacology. 1982;78:71-75.
Litten, R.Z.; Allen, J.; and Fertig, J. Pharmacotherapies for alcohol problems: A review of research with focus on developments since 1991. Alcoholism: Clinical and Experimental Research. 1996;20:859-876.
Little, H.J. Mechanisms that may underlie the behavioral effects of ethanol. Progress in Neurobiology. 1991;36:171-194.
Lozano Polo, J.L.; Gutierrez Mora, E.; Martinez Perez, V.; Santamaria Gutierrez, J.; Vada Sanchez, J.; and Vallejo Correas, J.A. [Effect of methadone or naltrexone on the course of transaminase[s] in parenteral drug users with hepatitis C virus infection.]. Revista Clinica Espanola. 1997;197(7):479-483. [pmid: 9411543].
Malec, T.S.; Malec, E.A.; and Doniger, M. Efficacy of buspirone in alcohol dependence: A review. Alcoholism: Clinical and Experimental Research. 1996;20(5):853-858.
Mason, B.J. Dosing issues in the pharmacotherapy of alcoholism. Alcohol: Clinical and Experimental Research. 1996;20(suppl. 7):10A-16A.
Mason, B.J.; Kocsis, J.H.; Ritvo, E.C.; and Cutler, R.B. A double-blind, placebo-controlled trial of desipramine for primary alcohol dependence stratified on the presence or absence of major depression. Journal of the American Medical Association. 1996;275:761-767.
Mason, B.J.; Ritvo, E.C.; Morgan, R.O.; Salvato, F.R.; Goldberg, G.; Welch, B.; and Mantero-Atienza, E. A double-blind, placebo-controlled pilot study to evaluate the efficacy and safety of oral nalmefene HCl for alcohol dependence. Alcohol: Clinical and Experimental Research. 1994;18(5):1162-1167.
Maxwell, S., and Shinderman, M. 1997.
McBride, W.J.; Murphy, J.M.; Yoshimoto, K.; Lumeng, L.; and Li, T.-K. Serotonin mechanisms in alcohol drinking behavior. Drug Development Research. 1993;30:170-177.
McCaul, M.E. Efficacy of naltrexone for alcoholics with and without comorbid opiate or cocaine dependence. In: Litten, R.Z., and Fertig, J., Chairs. International Update: New Findings on Promising Medications. Alcoholism: Clinical and Experimental Research. 1996;20(suppl.):216A-218A.
McGrath, P.J.; Nunes, E.V.; Stewart, J.W.; Goldman, D.; Agosti, V.; Ocepek-Welikson, K.; and Quitkin, F.M. Imipramine treatment of alcoholics with primary depression: A placebo-controlled clinical trial. Archives of General Psychiatry. 1996;53(3):232-240. [pmid: 8611060].
Mello, N.K.; Mendelson, J.H.; Kuehnle, J.C.; and Sellers, M.S. Operant analysis of human heroin self-administration and the effects of naltrexone. Journal of Pharmacology and Experimental Therapeutics. 1981;216:45-54.
Mihic, S.J., and Harris, R.A. GABA and the GABA_A_ receptor. Alcohol Health and Research World. 1997;21(2):127-131. [pmid: 15704348].
Miller, W.R., and Hester, R.K. Inpatient alcoholism treatment: Who benefits?. American Psychologist. 1986;41(7):794-805. [pmid: 3017164].
Naranjo, C.A.; Kadlec, K.E.; Sanhueza, P.; Woodley-Remus, D.; and Sellers, E.M. Fluoxetine differentially alters alcohol intake and other consummatory behaviors in problem drinkers. Clinical Pharmacology and Therapeutics. 1990;47:490-498.
Naranjo, C.A.; Sellers, E.M.; Roach, C.A.; Woodley, D.V.; Sanchez-Craig, M.; and Sykora, K. Zimelidine-induced variations in alcohol intake in non-depressed heavy drinkers. Clinical Pharmacology and Therapeutics. 1984;35:374-381.
Naranjo, C.A.; Sellers, E.M.; Sullivan, J.T.; Woodley, D.V.; Kadlec, K.; and Sykora, K. The serotonin uptake inhibitor citalopram attenuates ethanol intake. Clinical Pharmacology and Therapeutics. 1987;41:266-274.
Naranjo, C.A.; Sullivan, J.T.; Kadlec, K.E.; Woodley-Remus, D.V.; Kennedy, G.; and Sellers, E.M. Differential effects of viqualine on alcohol intake and other consummatory behaviors. Clinical Pharmacology and Therapeutics. 1989;46:301-309.
Nash, J.M. Addicted. Time. 1997;149(18):69-76.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Eighth Special Report to the U.S. Congress on Alcohol and Health From the Secretary of Health and Human Services, September 1993. 1994.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Neuroscience research and medications development. Alcohol Alert. 1996.
O'Brien, C.P.; Volpicelli, L.A.; and Volpicelli, J.R. Naltrexone in the treatment of alcoholism: A clinical review. Alcohol. 1996;13(1):35-39. [pmid: 8837932].
O'Connor, P.G.; Farren, C.K.; Rounsaville, B.J.; and O'Malley, S.S. A preliminary investigation of the management of alcohol dependence with naltrexone by primary care providers. American Journal of Medicine. 1997;103(6):477B482.
O'Connor, P.G., and Kosten, T.R. Rapid and ultrarapid opioid detoxification techniques. Journal of the American Medical Association. 1998;279(3):229B234.
O'Malley, S.S.; Croop, R.S.; Wroblewski, J.M.; Labriola, D.F.; and Volpicelli, J.R. Naltrexone in the treatment of alcohol dependence: A combined analysis of two trials. Psychiatric Annals. 1995;25:681-688.
O'Malley, S.S.; Jaffe, A.J.; Chang, G.; Rode, S.; Schottenfeld, R.S.; Meyer, R.E.; and Rounsaville, B. Six month follow-up of naltrexone and psychotherapy for alcohol dependence. Archives of General Psychiatry. 1996;53:217-224.
O'Malley, S.S.; Jaffe, A.J.; Chang, G.; Schottenfeld, R.S.; Meyer, R.E.; and Rounsaville, B. Naltrexone and coping skills therapy for alcohol dependence: A controlled study. Archives of General Psychiatry. 1992;49:881-887.
O'Malley, S.S.; Jaffe, A.J.; Rode, S.; and Rounsaville, B.J. Experience of a "slip" among alcoholics treated with naltrexone or placebo. American Journal of Psychiatry. 1996;153: 281-283.
O'Malley, S.S.; Krishnan-Sarin, S.; Farren, C.K.; O'Connor, P.G.; Golubchikov, V.; and Rounsaville, B.J. Predictors of naltrexone-induced nausea in alcohol-dependent subjects. Alcoholism: Clinical and Experimental Research. 1996;20:91A.
Oslin, D.; Liberto, J.; O'Brien, C.P.; Krois, S.; and Norbeck, J. Naltrexone as an adjunctive treatment for older patients with alcohol dependence. American Journal of Geriatric Psychiatry. 1997;5:324-332.
Pettinati, H.M. Use of serotonin selective pharmacotherapy in the treatment of alcohol dependence. Alcoholism: Clinical and Experimental Research. 1996;20(7):23A-29A.
Physicians Desk Reference (PDR), 51st ed. 1997.
Pickens, R.W.; Svikis, D.S.; McGue, M.; Lykken, D.T.; Heston, L.L.; and Clayton, P.J. Heterogeneity in the inheritance of alcoholism. Archives of General Psychiatry. 1991;48:19-28.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.I.; Judd, L.L.; and Goodwin, F.K. Comorbidity of mental disorders with alcohol and other drug use: Results from the epidemiologic catchment area (ECA) study. Journal of the American Medical Association. 1990;264:2511-2518.
Reid, L.D.; Delconte, J.D.; Nichols, M.L.; Bailey, E.J.; and Hubbard, C.J. Tests of opioid deficiency hypothesis hypotheses of alcoholism. Alcohol. 1991;8:247-257.
Reid, L.D.; Gardel, Gardell, L.R.; Chattopadyay, S.; and Hubbell, C.L. Periodic naltrexone and propensity to take alcoholic beverage. Alcohol Clinical and Experimental Research. 1996;20:1329-1334.
Research Institute on Addictions. New drug approved for alcoholism treatment: RIA study plays role in approval. Research in Brief. 1995.
Restak, R.R. The Mind. 1988.
Rice, D.P.; Kelma, S.; Miller, L.S.; and Dunmeyer, S. The Economic Costs to Society of Alcohol and Drug Abuse and Mental Illness: 1985. 1990.
Salloum, I.M.; Cornelius, J.R.; Thase, M.E.; Daley, D.C.; Kirisci, L.; and Spotts, C. Naltrexone utility in depressed alcoholics. Psychopharmacology Bulletin. 1998;34(1):111-115. [pmid: 9564207].
Sax, D.S.; Kornetsky, C.; and Kim, A. Lack of hepatotoxicity with naltrexone treatment. Journal of Clinical Pharmacology. 1994;34(9):898-901. [pmid: 7983232].
Schurman, R.A.; Kramer, P.D.; and Mitchell, J.B. The hidden mental health network: Treatment of mental illness by nonpsychiatric physicians. Archives of General Psychiatry. 1985;42:89-94.
Shapiro, S.; Skinner, E.A.; Kessler, L.G. Utilization of health and mental health services: Three epidemiological catchment area sites. Archives of General Psychiatry. 1984;41:971-978.
Siegel, S. Alcohol and opiate dependence: Reevaluation of the Victorian perspective. In: Cappell, H.D.; Glaser, F.B.; and Israel, Y., et al., eds. Research Advances in Alcohol and Drug Problems, Volume 9. New York: Plenum Press. 1986:pp. 279-314.
Sinclair, J.D. Morphine suppresses alcohol drinking regardless of prior alcohol access duration. Pharmacology, Biochemistry and Behavior. 1974;2:409-412.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies.http://www.health.org/pubs/nhsda/96hhs/rtst1012.htm#E9E12
Suzdak, P.D.; Schwarz, Schwartz, R.D.; Skolnick, P.; and Paul, S.M. Ethanol stimulates gamma-aminobutyric acid receptor-mediated chloride transport in rat brain synaptoneurosomes. Proceedings of the National Academy of Sciences. 1986;83:4071-4075.
Swift, R.M. Effect of naltrexone on human alcohol consumption. Journal of Clinical Psychiatry. 1995;56(suppl. 7):24-29.
Swift, R.M.; Whelihan, W.; Kuznetsov, O.; Buongiorno, G.; and Hsuing, H. Naltrexone-induced alterations in human ethanol intoxication. American Journal of Psychiatry. 1994;151:1463-1467.
Thiagarajan, A.B.; Mefford, I.N.; and Eskay, R.L. Single-dose ethanol administration activates the hypothalamic-pituitary axis: Exploration of the mechanism of action. Neuroendocrinology. 1989;50:427-432.
Ulm, R.R.; Volpicelli, J.R.; and Volpicelli, L.A. Opiates and alcohol self-administration in animals. Journal of Clinical Psychiatry. 1995;56(suppl. 7):5-14.
Verebey, K.; De Pace, A.; Jukofsky, D.; Volabka, J.V.; and Mule, S.J. Quantitative determination of 2-hydroxy-3-methoxy-6 beta-naltrexol (HMN), naltrexone, and 6 beta-naltrexol in human plasma, red blood cells, saliva, and urine by has liquid chromatography. Journal of Analytical Toxicology. 1980;4(1):33-37. [pmid: 6927049].
Verebey, K.; Volavka, J.; Mule, S.J.; and Resnick, R.B. Naltrexone: Disposition, metabolism, and effects after acute and chronic dosing. Clinical Pharmacology and Therapeutics. 1976;20: 315-328.
Volpicelli, J.R. 1995.
Volpicelli, J.R., and O'Brien, C.P. Introduction: Opioid involvement in alcohol dependence. Journal of Clinical Psychiatry. 1995;56(suppl. 7):3-4.
Volpicelli, J.R.; Alterman, A.I.; Hayashida, M.; and O'Brien, C.P. Naltrexone in the treatment of alcohol dependence. Archives of General Psychiatry. 1992;49:876-880.
Volpicelli, J.R.; Clay, K.L.; Watson, N.T.; and O'Brien, C.P. Naltrexone in the treatment of alcoholism: Predicting response to naltrexone. Journal of Clinical Psychiatry. 1995;56(suppl. 7):39-44.
Volpicelli, J.R.; Clay, K.L.; Watson, N.T.; and Volpicelli, L.A. Naltrexone and the treatment of alcohol dependence. Alcohol Health and Research World. 1994;18:272-278.
Volpicelli, J.R.; Rhines, K.C.; Rhines, J.S.; Volpicelli, L.A.; and O'Brien, C.P. Naltrexone and alcohol dependence: Role of subject compliance. Archives of General Psychiatry. 1997;54:737-743.
Volpicelli, J.R.; Ulm, R.R.; and Hopson, N. Alcohol drinking in rats during and following morphine injections. Alcohol. 1991;8:289-292.
Volpicelli, J.R.; Volpicelli, L.A.; and O'Brien, C.P. Medical management of alcohol dependence: Clinical use and limitations of naltrexone treatment. Alcohol and Alcoholism. 1995;30:789-798.
Wikler, W.A. Recent progress in research on the neurophysical basis of morphine addiction. American Journal of Psychiatry. 1948;105:328-338.
Wikler, W.A., and Pescor, F.T. Classical conditioning of a morphine abstinence phenomenon, reinforcement of opioid drinking behavior and "relapse" in morphine addicted rats. Psychopharmacologia. 1967;10:255-284.
Wilde, M.I., and Wagstaff, A.J. Acamprosate: A review of its pharmacology and clinical potential in the management of alcohol dependence after detoxification. Drugs. 1997;53(6):1038-1053. [pmid: 9179530].
Wise, R.A. Neuroleptics and operant behavior: The anhedonia hypothesis. Behavioral and Brain Science. 1982;5:39-87.
Zink, R.W.; Rohrbach, K.; and Froehlich, J.C. Naltrexone and fluoxetine act synergistically to decrease alcohol intake. Alcoholism: Clinical and Experimental Research. 1997;21(5):104A.