# Consensus Panel

## Chair

- Harvey A. Siegal, Ph.D.
- Professor and Director
- Substance Abuse Intervention Programs
- School of Medicine
- Wright State University
- Dayton, Ohio

## Workgroup Leaders

- James A. Hall, Ph.D.
- Associate Professor
- School of Social Work
- University of Iowa
- Iowa City, Iowa

- Howard Isenberg, M.A.
- Division Director
- Outpatient Treatment Services
- Northeast Treatment Centers
- Wilmington, Delaware

- Mary Nakashian
- Vice President and Director of Program Demonstration
- National Center on Addiction and Substance Abuse at Columbia University (CASA)
- New York, New York

- Richard C. Rapp, M.S.W.
- Co-Investigator, Assistant Professor
- Substance Abuse Intervention Programs
- School of Medicine
- Wright State University
- Dayton, Ohio

- M. Susan Ridgely, M.S.W., J.D.
- Associate Professor
- Department of Mental Health Law and Policy
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Patrick Sullivan, Ph.D.
- Division Director
- Division of Mental Health
- Family and Social Services Administration
- Indianapolis, Indiana

## Panelists

- Kathleen Andolina, R.N., M.S., C.S.
- Consultant
- Center for Case Management
- Natick, Massachusetts

- Barbara A. Blakeney, M.S., R.N., C.S., A.N.P.
- Principal Public Health Nurse
- Long Island Shelter
- Homeless Services and Addiction Services
- Public Health Commission
- Boston, Massachusetts

- Elizabeth Garcia, M.S.W.
- Director
- Managed Care
- Pinal Gila Behavioral Health Association
- Apache Junction, Arizona

- Margaret E. Hanna, M.Ed.
- Executive Director
- Bucks County Drug and Alcohol Commission
- New Britain, Pennsylvania

- Albert Hasson, M.S.W.
- Administrative Director
- Matrix Institute on Addictions
- Pizarro Treatment Center
- Los Angeles, California

- Judith Levy, Ph.D.
- Associate Professor
- School of Public Health
- University of Illinois
- Chicago, Illinois

- Duane C. McBride, Ph.D.
- Director of Research
- Behavioral Science Department
- Andrews University
- Berin Springs, Michigan

- Sylvia M. Ryan, M.A., B.A.
- Program Director
- Rocky Boy Health Board
- Rocky Boy Chemical Dependency Program
- Box Elder, Montana

- Anne C. Sowell, A.C.S.W., L.I.S.W.
- Coordinator of Community Projects
- Miracle Village
- MetroHealth Medical Center
- Cleveland, Ohio