# Appendix E - Field Reviewers

- Darlene Allen, M.S.
- Director
- Child Welfare Services
- Children's Friend and Services
- Providence, Rhode Island

- Andrea G. Barthwell, M.D.
- President
- Encounter Medical Group, P.C.
- Oak Park, Illinois

- Janice S. Bennett, M.S., C.S.A.C.
- Project Director
- Addiction Technology Transfer Center of Hawaii
- Honolulu, Hawaii

- Saroja A. Boaz
- Executive Director
- Intake Assessment and Referral Center
- Flint, Michigan

- Kim Bowman
- Director
- Government Services Center
- Chester County Department of Drug and and Alcohol Services
- West Chester, Pennsylvania

- Patricia Bradford, L.I.S.W., L.M.F.T., C.T.S.
- P.A. Bradford and Associates
- Columbia, South Carolina

- Mary Candace Burger, Ph.D.
- Assistant Professor
- Division of Geriatric Psychiatry
- Department of Psychiatry
- Vanderbilt Medical School
- Nashville, Tennessee

- Donna L. Caldwell, Ph.D.
- Senior Research Associate
- National Perinatal Information Center
- Providence, Rhode Island

- Donna H. Caum, M.S.S.W.
- Treatment Program Consultant
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, Tennessee

- Patrick R. Connelly
- Substance Abuse Program Consultant
- Division of Mental Health, Development Disabilities and Substance Abuse Services
- North Carolina Department of Health and Human Services
- Raleigh, North Carolina

- Gary Cox, Ph.D.
- Research Associate Professor
- ADAI
- University of Washington
- Seattle, Washington

- Martin C. Doot, M.D.
- Chief
- Division of Addiction Medicine
- Addiction Medicine/ Family Practice
- Lutheran General Hospital Advocate
- Park Ridge, Illinois

- Larry W. Dupree, Ph.D.
- Professor
- Department of Aging and Mental Health
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Mary E. Evans, R.N, Ph.D.
- Director of Research
- College of Nursing (MDC 22)
- University of South Florida
- Tampa, Florida

- Gary L. Fisher, Ph.D.
- Addiction Technology Transfer Center
- College of Education
- University of Nevada at Reno
- Reno, Nevada

- Steven L. Gallon, Ph.D.
- Program Director
- Office of Alcohol and Drug Abuse Programs
- Northwest Frontier Addiction Technology Transfer Center
- Salem, Oregon

- Theodore M. Godlaski, M.Div., I.C.D.C.
- Director of Community Treatment Project
- Center for Alcohol and Drug Research
- University of Kentucky
- Lexington, Kentucky

- Susan H. Godley, Ph.D.
- Senior Research Consultant
- Lighthouse Institute
- Chestnut Health Systems
- Bloomington, Illinois

- Darryl M. Grafton, M.Div., C.C.D.C.
- Clinical Supervisor
- Southeast Baltimore Center for Treatment
- Bayview Medical Center
- Johns Hopkins University
- Baltimore, MD

- Marge L. Hazen
- Systems and Funding Development Specialist
- Bureau of Substance Abuse Services
- Department of Health and Social Services
- State of Wisconsin
- Madison, Wisconsin

- Maya Hennessey, C.R.A.D.C.
- Women's Specialist
- Office of Special Programs
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois

- Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- Deborah Horan
- Manager
- Special Issues
- American College of Obstetrics and Gynecology
- Washington, D.C.

- Mary Beth Johnson, M.S.W.
- University of Missouri at Kansas City
- Kansas City, Missouri

- Patti Juliana
- Director of Clinical Services
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, New York

- Linda Kaplan
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Karen Kelly-Woodall, M.S., M.A.C., N.C.A.C.II
- Cork Institute
- Morehouse School of Medicine
- Atlanta, Georgia

- Michael W. Kirby, Jr., Ph.D.
- Chief Executive Officer
- Arapahoe House, Inc.
- Thornton, Colorado

- Mark L. Kraus, M.D.
- Westside Medical Group
- Waterbury, Connecticut

- Jeffrey N. Kushner
- Drug Court Administrator
- 22nd Judicial District
- Municipal Court of Saint Louis
- Saint Louis, Missouri

- Carl G. Leukefeld, D.S.W.
- Director
- Center on Drug and Alcohol Research
- University of Kentucky
- Lexington, Kentucky

- Sheera Lipshitz
- Director
- Assertive Treatment Team
- Brandywine Counseling, Inc.
- Wilmington, Delaware

- Bruce Lorenz, N.C.A.C. II
- Director
- Thresholds, Inc.
- Dover, Delaware

- Greg J. Madden, Ph.D.
- Research Associate
- Human Behavioral Pharmacology Laboratory
- University of Vermont
- Burlington, Vermont

- Jennifer Mankey, B.S.W., M.P.A.
- Project Director
- Denver Juvenile Justice Treatment Network
- Denver, Colorado

- Patrice Muchowski, Sc.D.
- Vice President
- Clinical Services
- Adcare Hospital of Worcester
- Worcester, Massachusetts

- Marlene O'Connell, R.N.
- Manager
- Behavioral Health Services
- Benefits Healthcare
- Great Falls, Montana

- Gennaro Ottomanelli, Ph.D.
- Director
- Division of Drug Dependence
- Kings County Addictive Disease Hospital
- Brooklyn, New York

- Elizabeth A. Peyton
- Executive Director
- National TASC
- Silver Spring, Maryland

- Ronald Pike, M.D.
- AdCare Hospital of Worcester
- Worcester, Massachusetts

- Deborah Powers
- IDU/AIDS Treatment Specialist
- State Methadone Authority
- State Department of Health and Family Services
- Madison, Wisconsin

- Lynda A. Price, Ph.D., I.C.A.D.C.
- Treatment Coordinator
- National Drug Commission
- Global House
- Hamilton, Bermuda

- Anthony Quintiliani, Ph.D.
- Clinical Director, Chief Psychologist
- Drug and Alcohol Division
- Howard Center for Human Services
- South Burlington, Vermont

- Patricia Reihl
- Coordinator
- Spring House
- Paramus, New Jersey

- Margaret M. Salinger, M.S.N., R.N., C.A.R.N.
- National Nurses Society on Addiction
- c/o Department of Veterans Affairs Medical Center
- Coatesville, Pennsylvania

- Anna M. Scheyett, M.S.W.
- Program Coordinator
- Behavioral Health Care Resource Program
- School of Social Work
- University of North Carolina at Chapel Hill
- Chapel Hill, North Carolina

- Stephen Schoen, Ph.D.
- Director
- Alcohol and Drug Awareness Program
- Department of State
- Medical Services
- Washington, D.C.

- Rene W. Seidel
- Director
- HIV Services
- Tarzana Treatment Center
- Tarzana, California

- Michael R. Sosin, M.S.W., Ph.D.
- Professor
- School of Social Service Administration
- University of Chicago
- Chicago, Illinois

- Flo A. Stein, M.P.A.
- Acting Section Chief
- Division of Mental Health, Developmental Disabilities and Substance Abuse Services
- Alcohol and Drug Services
- Raleigh, North Carolina

- Richard T. Suchinsky, M.D.
- Associate Chief
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Suzan Swanton
- Clinical Supervisor
- Glenwood Life Counseling Center
- Baltimore, Maryland

- Donald L. Tomlin
- Specialist
- Nashville Area Indian Health Service Substance Abuse
- Indian Health Service
- Cherokee, North Carolina

- Robert Walker, M.S.W., L.C.S.W., B.C.D.
- Director
- Bluegrass East Comprehensive Care Center
- Lexington, Kentucky

- Deborah Watson, Ph.D.
- Program Operations Manager
- Cleveland CARES Target Cities
- Alcohol and Drug Addiction Services Board
- Cleveland, Ohio

- Robert Whitney, M.D.
- Medical Consultant
- Office of Alcoholism and Substance Abuse
- Research Institute on Addiction
- Buffalo, New York

- Annette H. Wieser
- Regional Director
- Program Administration
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Janet S. Woodburn
- President
- Bridgeway Counseling Services, Inc.
- Saint Charles, Missouri