# Appendix D - Resource Panel

- Robert E. Anderson
- Director
- Quality Assurance Programs
- National Association of State Alcohol and Drug Abuse Directors, Inc.
- Washington, D.C.

- Lynn Aronson
- Housing Resource Manager
- Homeless Programs Branch
- Center for Mental Health Services
- Division of State and Community Systems Development
- Rockville, Maryland

- James Brennan
- Senior Staff Associate
- National Association of Social Workers
- Washington, D.C.

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Linda S. Foley, M.A.
- Member
- TIPS Editorial Advisory Board
- Director
- Treatment Improvement Exchange
- Health Systems Research, Inc.
- Washington, D.C.

- Helen Howerton, M.A.
- Director
- Child and Family Development
- Office of Planning, Research, and Evaluation
- Administration for Children and Families
- Washington, D.C.

- Mary Nakashian
- Vice President and Director of Program Demonstration
- National Center on Addiction and Substance Abuse
- Columbia University
- New York, NY

- Elizabeth Rahdert, Ph.D.
- Research Psychologist
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Larry Rickards, Ph.D.
- Director
- Intergovernmental Initiatives
- Homeless Programs Branch
- Center for Mental Health Services
- Rockville, Maryland

- Barbara Roberts, Ph.D.
- Senior Policy Analyst
- Executive Office
- White House Office of National Drug Control Policy
- Washington, D.C.

- Santo Ruiz
- Project Officer
- Community Support Program
- Division of State and Community Systems Development
- Center for Mental Health Services
- Rockville, Maryland

- Richard T. Suchinsky, M.D.
- Associate Chief
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.