# Appendix C - Bibliography

Adams, W.L.; Barry, K.L.; and Fleming, M.F. (1996). Screening for problem drinking in older primary care patients. Journal of the American Medical Association.
Adams, W.L.; Yuan, Z.; Barboriak, J.J.; and Rimm, A.A. (1993). Alcohol-related hospitalizations of elderly people: Prevalence and geographic location in the United States. Journal of the American Medical Association.
Administration on Aging. A Profile of Older Americans http://www.aoa.dhhs.gov/aoa/pages/profil95.html.
Aldrich, M.S. Effects of alcohol on sleep. In: Gomberg, E.; Hedgedus, A.M.; and Zucker, R.A., eds. Alcohol Problems and Aging. Washington DC: National Institute on Alcohol Abuse and Alcoholism, in press.
Alterman, A.I.; Kushner, H.; and Holahan, J.M. (1990). Cognitive functioning and treatment outcome in alcoholics. Journal of Nervous and Mental Disorders.
American Psychiatric Association. (1987). Diagnostic and Statistical Manual of Mental Disorders , 3rd ed., revised. Washington, DC: American Psychiatric Association.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders , 4th ed. Washington, DC: American Psychiatric Association, 1994.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance-Related Disorders , 2nd ed. Washington, DC: American Society of Addiction Medicine, 1996.
Anda, R.F.; Williamson, D.F.; and Remington, P.L. (1988). Alcohol and fatal injuries among U.S. adults. Journal of the American Medical Association.
Annis, H.M. (1986). Is inpatient rehabilitation of the alcoholic cost effective? Con position. Advances in Alcohol and Substance Use 5:175.
Artaud-Wild, S.M.; Connor, S.L.; Sexton, G.; and Connor, W.E. (1993). Differences in coronary mortality can be explained by differences in cholesterol and saturated fat intakes in 40 countries but not in France and Finland. Circulation.
Atkinson, R. (1985). Persuading alcoholic patients to seek treatment. Comprehensive Therapy 11(11):16-24.
Atkinson, R.M. Age-specific treatment of older adult alcoholics . In: Gomberg, E.S.L.; Hegedus, A.M.; and Zucker, R.A., eds. Alcohol Problems and Aging . Rockville, MD: National Institute on Alcohol Abuse and Alcoholism, in press.
Atkinson, R.M. (1990). Aging and alcohol use disorders: Diagnostic issues in the elderly. International Psychogeriatrics 2:55-72.
Atkinson, R.M. (1994). Late onset problem drinking in older adults. International Journal of Geriatric Psychiatry 9:321-326.
Atkinson, R.M. (1984). Substance use and abuse in late life. In: Atkinson, R.M., ed. Alcohol and Drug Abuse in Old Age . Washington, DC: American Psychiatric Press.
Atkinson, R.M. (1995). Treatment programs for aging alcoholics. In: Beresford, T., and Gomberg, E., eds. Alcohol and Aging. New York: Oxford University Press.
Atkinson, R.M., and Ganzini, L. (1994). Substance abuse. In: Coffey, C.E., and Cummings, J.L., eds. Textbook of Geriatric Neuropsychiatry . Washington, DC: American Psychiatric Press.
Atkinson, R.M.; Ganzini, L.; and Bernstein, M.J. (1992). Alcohol and substance-use disorders in the elderly. In: Birren, J.E.; Sloane, R.B.; and Cohen, G.D., eds. Handbook of Mental Health and Aging , 2nd ed. San Diego, CA: Academic Press.
Atkinson, R.M., and Kofoed, L.L. (1982). Alcohol and drug abuse in old age: A clinical perspective. Substance and Alcohol Actions and Misuse.
Atkinson, R.M.; Tolson, R.L.; and Turner, J.A. (1993). Factors affecting outpatient treatment compliance of older male problem drinkers. Journal of Studies on Alcohol.
Atkinson, R.M.; Turner, J.A.; Kofoed, L.L.; and Tolson, R.L. (1985). Early versus late onset alcoholism in older persons: Preliminary findings. Alcoholism: Clinical and Experimental Research.
Babor, T.; Korner, P.; Wilber, C.; and Good, S. (1987). Screening and early intervention strategies for harmful drinkers: Initial lessons from the AMETHYST Project. Australian Drug and Alcohol Review.
Babor, T.F.; de la Fuenta, J.R.; Saunders, J.; and Grant, M. (1992). AUDIT: The Alcohol Use Disorders Identification Test: Guidelines for Its Use in Primary Health Care.
Babor, T.F., and Grant, M. (1992). Project on Identification and Management of Alcohol-Related Problems. Report on Phase II: A Randomized Clinical Trial of Brief Interventions in Primary Health Care.
Babor T.F.; Grant, M.; Acuda, W.; Burns, F.H.; Campillo, C.; DelBoca, F.K.; Hodgson, R.; Ivanets, N.N.; Lukomskya, M.; and Machuna, M. (1994). A randomized clinical trial of brief interventions in primary care: Summary of a WHO project. Addiction.
Balter, M.B. (1973). An analysis of psychotherapeutic drug consumption in the United States. In: Bowen, R.A., ed. Proceedings of the Anglo-American Conference on Drug Abuse: Etiology of Drug Abuse I. London: Royal Society of Medicine.
Barnas, C.; Rossmann, M.; Roessler, H.; Reimer, Y.; and Fleischhacker, W.W. (1992). Benzodiazepine and other psychotropic drug abuse by patients in a methadone maintenance program: Benzodiazepines and other psychotropic drugs abused by patients in a methadone maintenance program: Familiarity and preference. Journal of Clinical Psychopharmacology.
Beresford, T.P. (1995a). Alcohol and aging: Looking ahead. In: Beresford, T.P., and Gomberg, E., eds. Alcohol and Aging . New York: Oxford University Press.
Beresford, T.P. (1995b). Alcoholic elderly: Prevalence, screening, diagnosis, and prognosis. In: Beresford, T.P, and Gomberg, E., eds. Alcohol and Aging . New York: Oxford University Press.
Beresford, T.P.; Blow, F.C.; Brower, K.J.; Adams, K.M.; and Hall, R.C.W. i. (1988). Alcoholism and aging in the general hospital. Psychosomatics.
Beresford, T.P., and Lucey, M.R. (1995). Ethanol metabolism and intoxication in the elderly. In: Beresford, T.P., and Gomberg, E.S., eds. Alcohol and Aging . New York: Oxford University Press.
Bezchlibnyk-Butler, K.Z., and Jeffries, J.J., eds. (1995). Clinical Handbook of Psychotropic Drugs, 5th ed. Toronto, Canada: Hogrefe & Huber.
Bien, T.H.; Miller, W.R.; and Tonigan, J.S. (1993). Brief interventions for alcohol problems: A review. Addiction.
Blazer, D.; Hughes, D.C.; and George, L.K. (1987b). The epidemiology of depression in an elderly community population. Gerontologist.
Blow, F.C. The spectrum of alcohol interventions for older adults. In: Gomberg, E.S.L.; Hegedus, A.M.; and Zucker, R.A., eds. Alcohol Problems and Aging. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism, in press.
Blow, F.C.; Brower, K.J.; Schulenberg, J.E.; Demo-Dananberg, L.M.; Young, J.P.; and Beresford, T.P. (1992a). The Michigan Alcoholism Screening Test - Geriatric Version (MAST-G): A new elderly-specific screening instrument. Alcoholism: Clinical and Experimental Research.
Blow, F.C.; Walton, M.A.; Chermack, S.T.; Mudd, S.A.; Brower, K.J.; and Comstock, M.A. (1997). Treatment outcome for elderly alcoholics following elder-specific inpatient treatment.
Booth, B.M.; Blow, F.C.; Cook, C.A.; Bunn, J.Y.; and Fortney, J.C. (1992). Age and ethnicity among hospitalized alcoholics: A nationwide study. Alcoholism: Clinical and Experimental Research.
Brennan, P.L., and Moos, R.H. (1996). Late-life problem drinking: Personal and environmental risk factors for 4-year functioning outcomes and treatment seeking. Journal of Substance Abuse.
Brower, K.J.; Mudd, S.; Blow, F.C.; Young, J.P.; and Hill, E.M. (1994). Severity and treatment of alcohol withdrawal in elderly versus younger patients. Alcoholism: Clinical and Experimental Research.
Brown, S.A., and Schuckit, M.A. (1988). Changes in depression among abstinent alcoholics. Journal of Studies on Alcohol.
Butler, R.N. (1969). Age-ism: Another form of bigotry. Gerontologist.
Butler, R.N., and Lewis, M.I. (1977). Aging and Mental Health.
Campbell, P.R. (1996). Population Projections for States by Age, Sex, Race, and Hispanic Origin: 1995 to 2025. Washington, DC: U.S. Bureau of the Census, Population Division, PPl-47.
Carethers, M. (1992). Health promotion in the elderly. American Family Physician 45:2253-2259.
Carlen, P.L.; McAndrews, M.P.; Weiss, R.T.; Dongier, M.; Hill, J.M.; Menzano, E.; Farcnik, K.; Abarbanel, J.; and Eastwood, M.R. (1994). Alcohol-related dementia in the institutionalized elderly. Alcoholism: Clinical and Experimental Research.
Cartensen, Carstensen L.L.; Rychtarik, R.G.; and Prue, D.M. (1985). Behavioral treatment of the geriatric alocohol alcohol abuser: A long-term follow-up study. Addictive Behaviors.
Center for Substance Abuse Treatment. (1995a). Detoxification from Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series, Number 19. DHHS Pub. No. (SMA) 95-3046. Washington, DC: U.S. Government Printing Office.
Center for Substance Abuse Treatment. (1996). Rural Issues in Alcohol and Other Drug Abuse Treatment . Technical Assistance Publication (TAP) Series, Number 10. DHHS Pub. No. (SMA) 96-3099. Washington, DC: U.S. Government Printing Office.
Center for Substance Abuse Treatment. (1995b). Treating Alcohol and Other Drug Abusers in Rural and Frontier Areas . Technical Assistance Publication (TAP) Series, Number 17. DHHS Pub. No. (SMA) 95-3054. Washington, DC: U.S. Government Printing Office.
Chapman, C.R., and Hill, C.F. (1989). Prolonged morphine self-administration and addiction liability. Cancer.
Chermack, S.T.; Blow, F.C.; Hill, E.M.; and Mudd S.A. (1996). The relationship between alcohol symptoms and consumption among older drinkers. Alcoholism: Clinical and Experimental Research.
Chick, J.; Ritson, B.; Connaughton, J.; and Stewart, A. (1988). Advice versus treatment for alcoholism: A controlled trial. British Journal of Addictions.
Ciraulo, D.A.; Shader, R.I.; Greenblatt, D.J.; and Creelman, W. (1995). Drug Interactions in Psychiatry , 2nd ed. Baltimore: Williams & Wilkins.
Closser, M.H., and Blow, F.C. (1993). Special populations: Women, ethnic minorities, and the elderly. Psychiatric Clinics of North America.
Colsher, P.L.; Wallace, R.B.; Pomrehn, P.R.; LaCroix, A.Z.; Cornoni-Huntley, J.; Blazer, D.; Scherr, P.A.; Berkman, L.; and Hennekens, C.H. (1990). Demographic and health characteristics of elderly smokers: Results from established populations for epidemiologic studies of the elderly. American Journal of Preventative Medicine.
Cook, B.; Winokur, G.; Garvey, M.; and Beach, V. (1991). Depression and previous alcoholism in the elderly. British Journal of Psychiatry.
Cooperstock, R., and Parnell, P. (1982). Research on psychotropic drug use: A review of findings and methods. Social Science and Medicine.
Cox, J.L. (1993). Smoking cessation in the elderly patient. Clinics in Chest Medicine 14(3):423-428.
Culebras, A. (1992). Update on disorders of sleep and the sleep-wake cycle. Psychiatric Clinics of North America 15:467-489.
Curtis, J.R.; Geller, G.; Stokes, E.J.; Levine, D.M.; and Moore, R.D. (1989). Characteristics, diagnosis, and treatment of alcoholism in elderly patients. Journal of the American Geriatrics Society.
D'Archangelo, E. (1993). Substance abuse in later life. Canadian Family Physician 39:1986-1993.
Davidson, D.M. (1989). Cardiovascular effects of alcohol. Western Journal of Medicine 151:430-439.
DeHart, S.S., and Hoffmann, H.G. (1995). Screening and diagnosis of "alcohol abuse and dependence" in older adults. International Journal of the Addictions.
Derogatis, L.R. (1994b). Symptom Checklist-90-Revised (SCL-90-R): Administration, Scoring, and Procedures Manual, 3rd ed. Minneapolis, MN: National Computer Systems.
Derogatis, L.R.; and Melisaratos, N. (1983). The Brief Symptom Inventory: An introductory report. Psychological Medicine.
DiClemente, C.C., and Hughes, S.O. (1990). Stages of change profiles in alcoholism treatment. Journal of Substance Abuse.
Dobson, K.S., ed. (1988). Handbook of Cognitive-Behavioral Therapies . New York: Guilford Press.
Douglass, R.L. (1984). Aging and alcohol problems: Opportunities for socioepidemiologic research. In: Galanter, M., ed. Recent Developments in Alcoholism . New York: Plenum Press.
Droller, H. (1964). Some aspects of alcoholism in the elderly. Lancet 1:137-139.
Dufour, M., and Fuller, R.K. (1995). Alcohol in the elderly. Annual Review of Medicine.
Dunlop. J. (1990). Peer groups support seniors fighting alcohol and drugs. Aging 361:28-32.
Dunlop, J.; Skorney, B.; and Hamilton, J. (1982). Group treatment for elderly alcoholics and their families. Social Work in Groups.
Dupree, L.W.; Broskowski, H.; and Schonfeld, L. (1984). The Gerontology Alcohol Project: A behavioral treatment program for elderly alcohol abusers. Gerontologist.
Egan, G. (1994). The Skilled Helper: A Problem-Management Approach to Helping, 5th ed. Pacific Grove, CA: Brooks/Cole.
Ensrud, K.E.; Nevitt, M.C.; Yunis, C.; Cauley, J.A.; Seeley, D.G.; Fox, K.M.; and Cummings, S.R. (1994). Correlates of impaired function in older women. Journal of the American Geriatrics Society.
Falvo, D. (1994). Effective Patient Education: A Guide to Increased Compliance, 2nd ed. Gaithersburg, MD: Aspen.
Falvo, D.R.; Holland, B.; Brenner, J.; and Benshoff, J.J. i. (1990). Medication use practices in the ambulatory elderly. Health Values.
Finch, J., and Barry, K.L. (1992). Substance use in older adults. In: Fleming, M., and Barry, K., eds. Addictive Disorders . St. Louis, MO: Mosby/Yearbook Medical Publishers.
Finkel, S.I. (1990). Group psychotherapy with older people. Hospital and Community Psychiatry 41:1189-1191.
Finlayson, R.; Hurt, R.; Davis, L.; and Morse, R. (1988). Alcoholism in elderly persons: A study of the psychiatric and psychosocial features of 216 inpatients. Mayo Clinic Proceedings.
Finlayson, R.E. (1995b). Misuse of prescription drugs. International Journal of the Addictions 30(13&14):1871-1901.
Finlayson, R.E. (1984). Prescription drug abuse in older persons. In: Atkinson, R.M., ed. Alcohol and Drug Abuse in Old Age . Washington, DC: American Psychiatric Press.
Finlayson, R.E., and Hurt, R.D. Medical consequences of heavy drinking by the elderly. In: Gomberg, E.; Hedgedus, A.M.; and Zucker, R.A., eds. Alcohol Problems and Aging. Washington DC: National Institute on Alcohol Abuse and Alcoholism, in press.
Finlayson, R.E.; Maruta T.; Morse, R.M.; and Martin, M.A. (1986a). Substance dependence and chronic pain: Experience with treatment and follow-up results. Pain.
Finney, J.W., and Monahan, S.C. (1996). The cost-effectiveness of treatment for alcoholism: A second approximation. Journal of Studies on Alcohol.
First, M.B.; Spitzer, R.L.; Gibbon, M.; and Williams, J.B.W. (1996). Structured Clinical Interview for DSM-IV Axis I Disorders-Patient Edition (SCID-I/P, Version 2.0).
Fitzgerald, J.L., and Mulford, H.A. (1992). Elderly versus younger problem drinker "treatment" and recovery experiences. British Journal of Addiction.
Fleming, M., and Barry, K. (1991). A three-sample test of a masked alcohol screening questionnaire. Alcohol and Alcoholism.
Fleming, M.; Barry, K.L.; Adams, W.; Manwell, L.B.; and Krecker, M. (1997a). Guiding Older Adult Lifestyles (Project GOAL): The effectiveness of brief physician advice for alcohol problems in older adults.
Fleming, M.F.; Barry, K.L.; Manwell, L.B.; Johnson, K.; and London, R. (1997b). Brief physician advice for problem alcohol drinkers: A randomized controlled trial in community-based primary care practices. Journal of the American Medical Association.
Forster, L.E.; Pollow, R.; and Stoller, E.P. i. (1993). Alcohol use and potential risk for alcohol-related adverse drug reactions among community-based elderly. Journal of Community Health.
Fouts, M., and Rachow, J. (1994). Choice of hypnotics in the elderly. P & T News.
Fredriksen, K.I. North of Market:. (1992). Older women's alcohol outreach program . Gerontologist 32:270-272.
Fuchs, C.S.; Stampfer, M.J.; Colditz, J.A.; Giovannucci, F.I.; Manson, T.E.; Kawachi, M.B.; Hunter, D.J.; Hankinson, S.E.; Hennekens, C.H.; Rosner, B.; Spelzer, F.E.; and Willet, W.C. (1995). Alcohol consumption and mortality among woman women. New England Journal of Medicine.
Gambert, S.R., and Katsoyannis, K.K. (1995). Alcohol-related medical disorders of older heavy drinkers. In: Beresford, T.P., and Gomberg, E., eds. Alcohol and Aging . New York: Oxford University Press.
Gatz, M., ed. (1995). Emerging Issues in Mental Health and Aging. Washington, DC: American Psychological Association.
Geller, G.; Levine, D.M.; Mamon, J.A.; Moore, R.D.; Bone, L.R.; and Stokes, E.J. (1989). Knowledge, attitudes, and reported practices of medical students and house staff regarding the diagnosis and treatment of alcoholism. Journal of the American Medical Association.
Glantz, M.D., and Backenheimer, M.S. (1988). Substance abuse among elderly women. Clinical Gerontologist.
Goldberg, R.J.; Burchfiel, C.M.; Reed, D.M.; Wergowske, G.; and Chiu, D. (1994). A prospective study of the health effects of alcohol consumption in middle-aged and elderly men: The Honolulu Heart Program. Circulation.
Gomberg, E.S.L. (1992a). "Elderly alcoholic men and women in treatment." Paper presented at the Research Society on Alcoholism Annual Scientific Meeting, San Diego, California.
Gomberg, E.S.L. (1992b). Medication problems and drug abuse. In: Turner, F.J., ed. Mental Health and the Elderly. New York: Free Press.
Gomberg, E.S.L. (1995). Older women and alcohol use and abuse. In: Galanter, M., ed. Recent Developments in Alcoholism: Volume 12. Alcoholism and Women. New York: Plenum Press.
Gomberg, E.S.L. (1988). Overview: Issues of alcohol use and abuse in the elderly population. Pride Institute Journal of Long Term Health Care 7:4-17.
Gomberg, E.S.L. (1993). Recent developments in alcoholism: Gender issues. In: Galanter, M., ed. Recent Developments in Alcoholism: Volume. 11 . New York: Plenum Press.
Gomberg, E.S.L. (1994). Risk factors for drinking over a woman's life span. Alcohol Health and Research World 18:220-227.
Goodman, A.C.; Holder, H.D.; and Nishiura, E. (1991). Alcoholism treatment offset effects: A cost model. Inquiry.
Goodwin, D.W., and Warnock, L.K. (1991). Alcoholism: A family disease. In: Grances, R.G., and Miller, S.L., eds. Clinical Textbook of Addictive Diseases. New York: Guiliford.
Gordon, T., and Kamel, W.B. (1983). Drinking and its relation to smoking, blood pressure, blood lipids, and uric acid. Archives of Internal Medicine.
Graham, K.; Clarke, D.; Bois, C.; Carver, V.; Dolenki, L.; Smythe, C.; Harrison, S.; Marshenan, J.; and Brett, P. (1996). Addictive behavior of older adults. Addictive Behaviors.
Grant, I. (1987). Alcohol and the brain: Neuropsychological correlates. Journal of Consulting and Clinical Psychology 55:310-324.
Grant, I.; Adams, K.; and Reed, R. (1984). Aging, abstinence, and medical risk factors in the prediction of neuropsychologic deficit among long-term alcoholics. Archives of General Psychiatry.
Gurnack, A.M. (1997). Older Adults' Misuse of Alcohol, Medicines, and Other Drugs. New York: Springer.
Guttmann, D. (1977). A Study of Legal Drug Use by Older Americans . Department of Health, Education, and Welfare Publication No. (ADM) 79-495. Washington, DC: Government Printing Office.
Haponik, E.F. (1992). Sleep disturbances of older persons: Physicians' attitudes. Sleep.
Harris, K.B., and Miller, W.R. (1990). Behavioural self-control training for problem drinkers: Components of efficacy. Psychology of Addictive Behaviour.
Hazelden Foundation. How To Talk to an Older Person Who Has a Problem With Alcohol or Medications . Center City, MN: Hazelden Foundation, 1991.
Health Care Financing Administration. http://www.hcfa.gov/pubforms/progman.htm [Accessed November 5, 1997; updated September 17, 1997].
Heather, N. (1995). Interpreting the evidence on brief interventions for excessive drinkers: The need for caution. Alcohol and Alcoholism 30:287-296.
Heather, N.; Campion, P.D.; Neville, R.G.; and MacCabe, D. (1987). Evaluation of a controlled drinking minimal intervention for problem drinkers in general practice (the DRAMS scheme). Journal of the Royal College for the General Practitioner.
Heller, D.A., and McClearn, G.E. (1995). Alcohol, aging, and genetics. In: Beresford, T.P, and Gomberg, E., eds. Alcohol and Aging. New York: Oxford University Press.
Helzer, J.E.; Bucholz, K.; and Robins, L.N. (1991a). Five communities in the United States: Results of the Epidemiologic Catchment Area Survey. In: Helzer, J.E., and Canino, G.J., eds. Alcoholism in North America, Europe, and Asia . New York: Oxford University Press.
Helzer, J.E.; Burnam, A.; and McEvoy, L.T. (1991b). Alcohol abuse and dependence. In: Robins, L.N., and Reigier, D.A., eds. Psychiatric Disorders in America: The Epidemiologic Catchment Area Study. New York: Free Press.
Hendricks, J.; Johnson, T.P.; Sheahan, S.L.; and Coons, S.J. (1991). Medication use among older persons in congregate living facilities. Journal of Geriatric Drug Therapy.
Herings, R.M.; Stricker, B.H.; de Boer, A.; Bakker, A.; and Sturmans, F. (1995). Benzodiazepines and the risk of falling leading to femur fractures: Dosage more important than elimination half-life. Archives of Internal Medicine.
Hill, H.F., and Chapman, C.R. (1989). Clinical effectiveness of analgesics in chronic pain states. In: NIDA Research Monograph Series, Number 95. Rockville, MD: National Institute on Drug Abuse.
Hodgson, R., and Rollnick, S. (1992). How brief intervention works: Representative cases as viewed by the health advisers. In: Babor, T.F., and Grant, M., eds. Project on Identification and Management of Alcohol-Related Problems: Report on Phase II. A Randomized Clinical Trial of Brief Interventions in Primary Health Care. Geneva, Switzerland: World Health Organization.
Holder, H.; Boyd, G.; Howard, J.; Flay, B.; Voas, R.; and Grossman, M. (1995). Alcohol-problem prevention research policy: The need for a phases research model. Journal of Public Health Policy.
Holder, H.D., and Blose, J.O. (1986). Alcoholism treatment and total health care utilization and costs: A four year longitudinal analysis of federal employees. Journal of the American Medical Association.
Holder, H.D.; Longabaugh, R.; Miller, W.R.; and Rubonis, A.V. (1991). The cost-effectiveness of treatment for alcoholism: A first approximation. Journal of Studies on Alcohol.
Hrubec, Z., and Omenn, G. (1981). Evidence of genetic predisposition to alcoholic cirrhosis and psychosis: Twin concordance for alcoholism and its end points by zygosity among male veterans. Alcoholism.
Hurt, R.D.; Eberman, K.A.; Slade, J.; and Karan, L. (1993). Treating nicotine addiction in patients with other addictive disorders. In: Orleans, C.T., and Slade, J., eds. Nicotine Addiction: Principles and Management . New York: Oxford University Press.
Hurt, R.D.; Finlayson, R.E.; Morse, R.M.; and Davis, L.J. (1988). Alcoholism in elderly persons: Medical aspects and prognosis of 216 patients. Mayo Clinic Proceedings.
Institute of Medicine. (1990). Broadening the Base of Treatment for Alcohol Problems. Washington, DC: National Academy Press.
Institute of Medicine. (1995). Federal Regulation of Methadone Treatment . Rettig, R., and Yarmolinsky, A., eds. Washington, DC: National Academy Press.
Janik, S., and Dunham, R. (1983). A nationwide examination of the need for specific alcoholism treatment programs for the elderly. Journal of Studies on Alcohol.
Jinks, M.J., and Raschko, R.R. (1990). A profile of alcohol and prescription drug abuse in a high-risk community-based elderly population. Drug Intelligence and Clinical Pharmacy.
Joseph, C.L. (1995). Alcohol and drug misuse in the nursing home. International Journal of the Addictions 30(13&14):1953-1983.
Joseph, C.L.; Ganzini, L.; and Atkinson, R. (1995). Screening for alcohol use disorders in the nursing home. Journal of the American Geriatrics Society.
Kahan, M.; Wilson, L.; and Becker, L. (1995). Effectiveness of physician-based interventions with problem drinkers: A review. Canadian Medical Journal.
Kaslow, F., and Robison, J.A. (1996). Long-term satisfying marriages: Perceptions of contributing factors. American Journal of Family Therapy.
Keeler, E.B.; Solomon, D.H.; Beck, J.C.; Mendenhall, R.C.; and Kane, R.L. (1982). Effect of patient age on duration of medical encounters with physicians. Medical Care.
King, M.B. (1986). Alcohol abuse and dementia. International Journal of Geriatric Psychiatry 1:31-36.
Klatsky, A.L.; Armstrong, M.A.; and Friedman, G.D. (1990). Risk of cardiovascular mortality in alcohol drinkers, ex-drinkers, and non-drinkers. American Journal of Cardiology.
Koenig, H.G, and Blazer, D.G., II. (1996). Depression. In: Birren, J.E., ed. Encyclopedia of Gerontology: Age, Aging, and the Aged . Vol. I. San Diego, CA: Academic Press.
Kofoed, L.L.; Tolson, R.L.; Atkinson, R.M.; Toth, R.L.; and Turner, J.A. (1987). Treatment compliance of older alcoholics: An elder-specific approach is superior to "mainstreaming.". Journal of Studies on Alcohol.
Kovar, M. (1977). Health of the elderly and use of health services. Public Health Reports 92:9-19.
Kranzler, H.R.; Babor, T.F.; and Lauerman, R.J. (1990). Problems associated with average alcohol consumption and frequency of intoxication in a medical population. Alcoholism: Clinical and Experimental Research.
LaCroix, A.Z.; Guralnik, J.M.; Berkman, L.F.; Wallace, R.B.; and Satterfield, S. (1993). Maintaining mobility in late life: Smoking, alcohol consumption, physical activity, and body mass index. American Journal of Epidemiology.
Lawton, M.P., and Brody, E.M. (1969). Assessment of older people: Self-maintaining and instrumental activities of daily living. Gerontologist.
Lebowitz, B.D.; Light, E.; and Bailey F. (1987). Mental health center services for the elderly: The impact of coordination with area agencies on aging. Gerontologist.
Leveille, S.G.; Buchner, D.M.; Koespell, T.D.; McCloskey, L.W.; Wolf, M.E.; and Wagner, E.H. (1994). Psychoactive medications and injurious motor vehicle collisions involving older drivers. Epidemiology.
Liberto, J.G.; Oslin, D.W.; and Ruskin, P.E. (1992). Alcoholism in older persons: A review of the literature. Hospital and Community Psychiatry.
Linn, M.W. (1978). Attrition of older alcoholics from treatment. Addictive Diseases: An International Journal.
Liskow, B.I.; Rinck, C.; Campbell, J.; and DeSouza, C.i. (1989). Alcohol withdrawal in the elderly. Journal of Studies on Alcohol.
Lord, S.R.; Antsey, Anstey, K.J.; Williams, P.; and Ward, J.A. (1995). Psychoactive medication use, sensori-motor function and falls in older women. British Journal of Clinical Pharmacology.
Mammo, A., and Weinbaum, D.F. (1993). Some factors that influence dropping out from outpatient alcoholism treatment facilities. Journal of Studies on Alcohol.
McCrady, B.S., and Langenbucher, J.W. (1996). Alcoholism Alcohol treatment and health care system reform. Archives of General Psychiatry.
McHorney, C.A.; Ware, J.E.; and Raczek, A.E. (1993). The MOS 36-Item Short-Form Health Survey (SF-36): II. Psychometric and clinical tests of validity of measuring physical and mental health constructs. Medical Care.
McLellan, A.T., and Durell, J. (1996). Outcome evaluation in psychiatric and substance abuse treatments: Concepts, rationale, and methods. In: Sederer, L., and Dickey, B., eds. Outcomes Assessment in Clinical Practice. Baltimore, MD: Williams & Wilkins.
McLellan, A.T.; Luborsky, L.; Cacciola, J.; and Griffith, J. (1985). New data from the addiction severity index: Reliability and validity in three centers. Journal of Nervous Disease.
McLellan, A.T.; O'Brien, C.P.; Metzger, D.; Alterman, A.I.; Cornish, J.; and Urschel, H. (1992). How effective is substance abuse treatment - compared to what? In: O'Brien, C.P., and Jaffee, J., eds. Advances in Understanding the Addictive States. New York: Raven Press.
Meichenbaum, D., and Turk, D. (1987). Facilitating Treatment Adherence: A Practitioner's Guidebook. New York: Plenum Press.
Mellinger, G.D.; Balter, M.B.; and Uhlenhuth, E.H. (1985. 1984.). Prevalence and correlates of the long-term use of anxiolytics. Journal of the American Medical Association.
Miller, F.; Whitcup, S.; Sacks, M.; and Lynch, P.E. (1985). Unrecognized drug dependence and withdrawal in the elderly. Drug and Alcohol Dependence.
Miller, W.R., and Munoz, R.F. (1976). How To Control Your Drinking . Englewood Cliffs, NJ: Prentice-Hall.
Miller, W.R., and Rollnick, S. (1991). Motivational Interviewing . New York: Guilford Press.
Miller, W.R., and Sanchez, V.C. (1994). Motivating young adults for treatment and lifestyle change. In: Howard, G.S., and Nathan, P.E. Alcohol Use and Misuse by Young Adults . South Bend, IN: University of Notre Dame Press.
Miller, W.R., and Taylor, C.A. (1980). Relative effectiveness of bibliotherapy, individual and group self-control training in the treatment of problem drinkers. . Addictive Behaviors.
Minnis, J. (1988). Toward an understanding of alcohol abuse among the elderly: A sociological perspective. Journal of Alcohol and Drug Education 33(3):32-40.
Moeller, F.G.; Gillin, J.C.; Irwin, M.; Golshan, S.; Kripke, D.F.; and Schuckit, M. (1993). A comparison of sleep EEGs in patients with primary major depression and major depression secondary to alcoholism. Journal of Affective Disorders.
Moore, R.D.; Bone, L.R.; Geller, G.; Mamon, J.A.; Stokes, E.J.; and Levine, D.M. (1989). Prevention, Prevalence, detection and treatment of alcoholism in hospitalized patients. Journal of the American Medical Association.
Moos, R.H.; Mertens, J.R.; and Brennan, P.L. (1993). Patterns of diagnosis and treatment among late-middle-aged and older substance abuse patients. Journal of Studies on Alcohol.
Myers, J.E. (1989). Adult Children and Aging Parents . Alexandria, VA: American Counseling Association.
Myers, J.E., and Schwiebert, V. (1996). Competencies for Gerontological Counseling . Alexandria, VA: American Counseling Association.
Myers, J.K.; Weissman, M.M.; Tischler, G.L.; Holzer, C.E., III; Leaf, P.J.; Orvaschel, H.; Anthony, J.C.; Boyd, J.H.; Burke, J.D., Jr.; Kramer, M.; and Stolzman, R. (1984). Six-month prevalence of psychiatric disorders in three communities: 1980-1982. Archives of General Psychiatry.
National Institute on Alcohol Abuse and Alcoholism. (1988). Alcohol and aging. Alcohol Alert 2:1-5.
National Institute on Alcohol Abuse and Alcoholism . (1995). The Physicians' Guide to Helping Patients With Alcohol Problems . NIH Pub. No. 95-3769. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism.
National Institutes of Health. (1991). Consensus Development Conference Statement. Diagnosis and Treatment of Depression in Late Life 9(3):1-27.
National Institutes of Health. (1990). Consensus Development Conference Statement. The Treatment of Sleep Disorders in Older People 8(3):1-22.
Nitcher, R.L.; Burke, W.J.; Roccaforte, W.H.; and Wengel, S.P. (1993). A collateral source version of the geriatric depression rating scale. American Journal of Geriatric Psychiatry.
Orleans, C.T.; Jepson, C.; Resch, N.; and Rimer, B.K. (1994a). Quitting motives and barriers among older smokers. Cancer.
Oslin, D.; Liberto, J.G.; O'Brien, J.; Krois, S.; and Norbeck, J. (1997). Naltrexone as an adjunctive treatment for older patients with alcohol dependence. American Journal of Geriatric Psychiatry.
Oslin, D.W.; Pettinati, H.; Volpicelli, J.R.; and Katz, I.R. (1997). "Enhancing treatment compliance in elderly alcoholics: A new psychosocial intervention model.".
Osterling, A., and Berglund, M. (1994). Elderly first time admitted alcoholics: A descriptive study on gender differences in a clinical population. Alcoholism: Clinical and Experimental Research.
Parker, D.A.; Parker, E.S.; Brody, J.A.; and Schoenberg, R. (1983). Alcohol use and cognitive loss among employed men and women. American Journal of Public Health.
Peele, S. (1990). Research issues in assessing addiction treatment efficacy: How cost effective are Alcoholics Anonymous and private treatment centers? Drug and Alcohol Dependency 25:179-182.
Persson, J., and Magnusson, P.H. (1989). Early intervention in patients with excessive consumption of alcohol: A controlled study. Alcohol.
Piland, B. (1979). The aging process and psychoactive drug use in clinical treatment. In: The Aging Process and Psychoactive Drug Use . National Institute on Drug Abuse Services Research Monograph. Department of Health, Education, and Welfare Pub. No. (ADM) 79-813. Washington, DC: U.S. Government Printing Office.
Plomp, R. (1978). Auditory handicap of hearing impairment and the limited benefit of hearing aids. Journal of the Acoustic Society of America 63:533-549.
Pollock, V.; Schneider, L.; Zemansky, M.; Gleason, R.; and Pawluczyk, S. (1992). Topographic quantitative EEG amplitude in recovered alcoholics. Psychiatry Research: Neuroimaging.
Portenoy, R.K. (1993). Therapeutic use of opioids: Prescribing and control issues. In: Cooper J.R.; Czechowicz D.J.; Molinari S.P.; Petersen, R.C., eds. Impact of Prescription Drug Diversion Control Systems on Medical Practice and Patient Care. NIDA Research Monograph Series, Number 131. NIH Pub. No. 93-3507. Washington, DC: U.S. Government Printing Office.
Powers, R.B., and Osborne, J.G. (1976). Fundamentals of Behavior.
Prochaska, J., and DiClemente, C. (1986). Toward a comprehensive model of change. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors: Processes of Change . New York: Plenum Press.
Prochaska, J.O., and DiClemente, C.C. (1985). Processes and stages of change in smoking, weight control, and psychological distress. In: Schiffman, S., and Wills, T., eds. Coping and Substance Abuse . New York: Academic Press.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. (1992). In search of how people change: Applications to addictive behaviors. American Psychologist.
Rains, V., and Ditzler, T. (1993). Alcohol use disorders in cognitively impaired patients referred for geriatric assessment. Journal of Addictive Diseases.
Ray, W.A. (1992). Psychotropic drugs and injuries among the elderly: A review. Journal of Clinical Psychopharmacology 12:386-396.
Ray, W.A.; Thapa, P.B.; and Shorr, R.I. (1993). Medications and the older driver. Clinics in Geriatric Medicine.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.J.; Judd, L.L.; and Goodwin, F.K. (1990). Comorbidity of mental disorders with alcohol and other drug abuse. Journal of the American Medical Association.
Rice, C.; Longabaugh, R.; Beattie, M.; and Noel, N. (1993). Age group differences in response to treatment for problematic alcohol use. Addiction.
Rimer, B.K. and Orleans, C.T. (1994). Tailoring smoking cessation for older adults. Cancer.
Rodrigo, E.K.; King, M.B.; and Williams, P. (1988). Health of long term benzodiazepine users. British Medical Journal.
Roy, W., and Griffin, M. (1990). Prescribed medications and the risk of falling. Topics in Geriatric Rehabilitation.
Ruthazer, R., and Lipsitz, L.A. (1993). Antidepressants and falls among elderly people in long-term care. American Journal of Public Health.
Salthouse, T.A. (1985). Speed of behavior and its implications for cognition. In: Birren. J.E., and Schaie, K.W., eds. Handbook of the Psychology of Aging . New York: Van Nostrand and Reinhold.
Salzman, C. (Task Force Chair). (1990). Benzodiazepine Dependence, Toxicity, and Abuse: A Task Force Report of the American Psychiatric Association. Washington, DC: American Psychiatric Press.
Salzman, C. (1993a). Benzodiazepine treatment of panic and agoraphobia syndromes: agoraphobic symptoms: Use, dependence, toxicity, abuse. Journal of Psychiatric Research 27:97-110.
Salzman, C. (1993b). Issues and controversies regarding benzodiazepine use. In: Cooper, J.R.; Czechowicz, D.J.; Molinari, S.P.; and Petersen, R.C., eds. Impact of Prescription Drug Diversion Control Systems on Medical Practice and Patient Care . NIDA Research Monograph Series, Number 131. NIH Pub. No. 93-3507. Washington, DC: U.S. Government Printing Office.
Sanchez-Craig, M.; Neumann, B.; Souza-Formigoni, M.; and Rieck, L. (1991). Brief treatment for alcohol dependence: Level of dependence and treatment outcome. . Alcohol and Alcoholism Supplement.
Saunders, P.A. (1994). Epidemiology of alcohol problems and drinking patterns. In: John, R.M.; Copeland, M.T.; Aboou-Saleh, M.T.; and Blazer, D.G., eds. Principles and Practice of Geriatric Psychiatry . New York: Wiley.
Saunders, P.A.; Copeland, J.R.; Dewey, M.E.; Davidson, I.A.; McWilliam, C.; Sharma, V.; and Sullivan, C. (1991). Heavy drinking as a risk factor for depression and dementia in elderly men: Findings from the Liverpool Longitudinal Community Study. British Journal of Psychiatry.
Schmidt, A.; Barry, K.; and Fleming, M. (1995). A new screening test for the detection of problem drinkers: The Alcohol Use Disorders Identification Test (AUDIT). Southern Medical Journal.
Schonfeld, L., and Dupree, L.W. (1991). Antecedents of drinking for early- and late-onset elderly alcohol abusers. . Journal of Studies on Alcohol.
Schonfeld, L., and Dupree, L.W. (1995). Treatment approaches for older problem drinkers. International Journal of the Addictions.
Schuckit, M.A. (1989). Drug and Alcohol Abuse , 3rd ed. New York: Plenum Press.
Schuckit, M.A. (1977). Geriatric alcoholism and drug abuse. Gerontologist 17:168-174.
Schuckit, M.A., and Morrissey, E.R. (1979). Drug abuse among alcoholic women. American Journal of Psychiatry.
Scott, J.; Williams, J.M.G.; and Beck, A . (1989). Cognitive Therapy in Clinical Practice: An Illustrative Casebook. London, UK: Routledge.
Shaper, A.G.; Wannamethee, G.; and Walker, M. (1988). Alcohol and mortality in British men: Explaining the U-shaped curve. Lancet.
Sheahan, S.L.; Hendricks, J.; and Coons, S.J. (1989). Drug misuse among the elderly: A covert problem. Health Values.
Sheikh, J.I., and Yesavage, J.A. (1986). Geriatric Depression Scale (GDS): Recent evidence and development of a shorter version. Clinical Gerontologist.
Simon, A.; Epstein L.; and Reynolds L. (1968). Alcoholism in the geriatric mentally ill. Geriatrics.
Smith, J.W. (1995). Medical manifestations of alcoholism in the elderly. International Journal of the Addictions 30(13&14):1749-1798.
Smith, V. (1996). Symptom checklist-90-revised (SCL-90-R) and the brief symptom inventory (BSI). In: Sederer, L., Dickey, B., eds. Outcomes Assessment in Clinical Practice . Baltimore: Williams & Wilkins.
Sobell, L.C.; Brown, J.; Leo, G.I.; and Sobell, M.B. (1996). The reliability of the alcohol timeline followback when administered by telephone and by computer. Drug and Alcohol Dependence.
Solomon, K.; Manepalli, J.; Ireland, G.A.; and Mahon, G.M. (1993). Alcoholism and prescription drug abuse in the elderly: St. Louis University grand rounds. Journal of the American Geriatric Society.
Speirs, C.J.; Navey, F.L.; Broods, D.J.; and Impallomeni, M.G. (1986). Opisthotonos and benzodiazepine withdrawal in the elderly. Lancet.
Spiegler, M.D., and Guevremont, D.C. (1993). Contemporary Behavior Therapy. Pacific Grove, CA: Brooks/Cole.
Spitzer, R.L., and Williams, J.B. (1985). Structured Clinical Interview for DSM-III (SCID).
Srivastava, L.M.; Vasisht, S.; Agarwal, D.P.; and Goedde, H.W. (1994). Relation between alcohol intake, lipoproteins and coronary artery disease: The interest continues. Alcohol and Alcoholism.
Stewart, A.L.; Hays, R.D.; Ware, J.E., Jr. (1988). The MOS Short-Form General Health Survey: Reliability and validity in a patient population. Medical Care 26:724-735.
Stinson, F.S.; Dufour, M.C.; and Bertolucci, D. i. (1989). Alcohol-related morbidity in the aging population. Alcohol Health and Research World.
Swan, G.E.; Carmelli, D.; Rosenman, R.H.; Fabsitz, R.R.; and Christian, J.C. (1990). Smoking and alcohol consumption in adult male twins: Genetic heritability and shared environmental influences. Journal of Substance Abuse.
Tarter, R.E. (1995). Cognition, aging, and alcohol. In: Beresford, T.P., and Gomberg, E., eds. Alcohol and Aging . New York: Oxford University Press.
Temple, M.T., and Leino, E.V. (1989). Long-term outcomes of drinking: A 20 year longitudinal study of men. British Journal of Addiction.
Thomas-Knight, R. (1978). Treating alcoholism among the aged: The effectiveness of a special treatment program for older problem drinkers. Dissertation Abstracts International 39:3009.
Tobias, C.; Lippmann, S.; Pary, R.; Oropilla, T.; and Embry, C.K. (1989). Alcoholism in the elderly: How to spot and treat a problem the patient wants to hide. Postgraduate Medicine.
Tyas, S.L., and Rush, B.R. (1994). Trends in the characteristics of clients of alcohol/drug treatment in Ontario. Canadian Journal of Public Health.
U.S. Preventive Services Task Force. (1996). Guide to Clinical Preventive Services . Baltimore: Williams & Wilkins.
Vaillant, G.E.; Clark, W.; Cyrus, C.; Milofsky, E.S.; Kopp, J.; Wulsin, V.W.; and Mogielnicki, N.P. (1983). Prospective study of alcoholism treatment: Eight-year follow-up. American Journal of Medicine.
Velicer, W.F.; Prochaska, J.O.; Rossi, J.S.; and Snow, M.G. (1992). Assessing outcome in smoking cessation studies. Psychological Bulletin.
Vestal, R.E.; McGuire, E.A.; Tobin, J.D.; Andres, R.; Norris, A.H.; and Mezey, E. (1977). Aging and ethanol metabolism. Clinical Pharmacology and Therapeutics.
Vogel-Sprott, M., and Barret, Barrett, P. (1984). Age, drinking habits, and the effects of alcohol. Journal of Studies on Alcohol.
Wallace, P.; Cutler, S.; and Haines A. (1988). RandomizedRandomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. British Medical Journal.
Ware, J.E., Jr., and Sherbourne, C.D. (1992). The MOS 36-Item Short-Form Health Survey (SF-36): I. Conceptual framework and item selection. Medical Care 30:473-481.
Watson, Y.I.; Arfken, C.L.; and Birge, S.J. (1993). Clock completion: An objective screening test for dementia. Journal of the American Geriatrics Society.
Weintraub, M., and Handy, B.M. (1993). Benzodiazepines and hip fractures: fracture: The New York State experience. Clinical Pharmacology Therapy.
Wells, K.B.; Burnam, M.A.; Benjamin, B.; and Golding, J.M. (1990). Alcohol use and limitations in physical functioning in a sample of the Los Angeles general population. Alcohol and Alcoholism.
Wiens, A.N.; Menustik, C.E.; Miller, S.L.; and Schmitz, R.E. (1982/1983). Medical-behavioral treatment of the older alcoholic patient. American Journal of Drug and Alcohol Abuse.
Wilsnack, S.C., and Wilsnack, R.W. i. (1995). Drinking and problem drinking in U.S. women: Patterns and recent trends. Recent Developments in Alcoholism.
Winger, G. (1993). Other abused drugs: Benzodiazepines and sedatives. In: Fourth Triennial Report to Congress on Drug Abuse and Drug Abuse Research From the Secretary, Department of Health and Human Services. Rockville, MD: U.S. Department of Health and Human Services.
Wolfe, S.M.; Fugate, L.; Hulstrand, E.P.; and Kamimoto, L.E. (1988). Worst Pills, Best Pills: The Older Adult's Guide to Avoiding Drug-Induced Death or Illness. Washington, DC: Public Citizen Health Research Group.
Woods, J.H., and Winger, G. (1995). Current benzodiazepine issues. Psychopharmacology.
Wysowski, D.K.; Baum, C.; Ferguson, W.J.; Lundin, F.; Ng, M.J.; and Hammerstrom, T. (1996). Sedative-hypnotic drugs and risk of hip fracture. Journal of Clinical Epidemiology.
Zimberg, S. (1974). Two types of problem drinkers: Both can be managed. Geriatrics.